# Results

## Search Results

We retrieved 5,912 unique citations (Figure 2) and included seven studies (reported in eight publications). We identified six studies that compared NPWT with other wound care methods51–56 and one study (two publications) that compared two different NPWT devices.57, 58 Appendix C lists the excluded articles and the reason(s) that they were excluded.

We retrieved 96 protocols from ClinicalTrials.gov. Two protocols were deemed potentially relevant. One of these protocols was for a randomized controlled trial (RCT) that aimed to compare a NPWT with standard dressings among patients with pressure ulcers.59 This study was terminated because of a low recruitment rate. The second protocol was matched to one of the included studies57, 58 using the ClinicalTrials.gov registry number (NCT).60 We identified an additional seven protocols that compared NPWT with either other wound treatments or another NPWT device among patients with chronic wounds.61–67 However, we were unable to determine if these protocols met our eligibility criteria as information about the setting was not provided.

Figure 2 Summary of the literature search

* Total may exceed number in corresponding box, as articles could be excluded for more than one reason at this level. CINAHL = Cumulative Index to Nursing and Allied Health Literature; NPWT = negative pressure wound therapy

The figure shows the literature search via a vertical search flow diagram. From top to bottom, the first box shows the electronic databases that were searched; PubMed, Embase, Cochrane and CINAHL, and how many returns from the search for each database. Then there is a box to the right with handsearched articles. The next box has total retrieved titles. Then there is a box to the right with duplicates that were removed, then abstract review, then a box to the right with excluded titles, then another box to the right with reasons for exclusion at the abstract review level. Then article review, a box to the right with excluded titles, then another box to the right with reasons for exclusion at the articles review level. Finally, there is a box summarizing the included studies broken down by key question.

## Negative Pressure Wound Therapy Technologies Commercially Available in the U.S.

We searched the U.S. Food and Drug Administration Web site to identify NPWT technologies (Key Question 1). Supplemental information about available devices was obtained by reviewing the previous technology assessment on NPWT31 and through each manufacturer’s Web sites. Table 3 lists the NPWT technologies commercially available in the U.S. to treat wounds.

Table 3 Negative pressure wound therapy technologies commercially available in the U.S. to treat wounds

Manufacturer/Company | Model | Setting used
Atmos | Wound RX S 041 Wound pump | Hospital and home
Convatec | See IRB/Boehringer
Genadyne | Genadyne A4 Wound Vacuum System | Hospital and home
Innovative Therapies | SVEDMAN™ and SVED™ Wound Treatment Systems | Hospital and home
Invacare | MoblVac® | Hospital and home
IRB Medical Equipment/Boehringer Wound Systems/ConvaTec | Engenex® Advanced NPWT System | Hospital and home
Joerns (manufactured by Medela; distributed by Joerns) | Invia® Liberty™ Invia® Vario | Hospital and home
Kalypto Medical (acquired by Smith & Nephew) | NPD 1000™ Negative Pressure Wound Therapy System | Home
KCI (Kinetic Concepts, Inc.) | V.A.C.Via™ Therapy V.A.C.Ulta™ Therapy ActiV.A.C.^®^ Therapy V.A.C. ATS^®^ Therapy V.A.C. Freedom^®^ Therapy V.A.C. Instill^®^ Wound Therapy InfoV.A.C.^®^ Therapy ABThera™ Open Abdomen Negative Pressure Therapy (open abdominal wounds) | Hospital and home Hospital Hospital and home Hospital and home Hospital and home Hospital Hospital and home Hospital Home
MediTop BV/The Medical Company | Exusdex® wound drainage pump | Primarily hospital use but may be used at home
Medela | Invia® Liberty™ Invia® Vario Medela® Invia Liberty pump Invia® Motion™ | Hospital and home
Premco Medical Systems | Prodigy™ NPWT System (PMS-800 and PMS-800V) | Hospital and home
Prospera | PRO-I™ (stationary) PRO-II™ (portable) PRO-III™ | Hospital and home Home Hospital and home
Smith and Nephew | Renasys EZ Plus Renasys Go PICO V1STA (previously by Blue Sky Medical Group) EZCare (previously by Blue Sky Medical Group) | Hospital and home Hospital and home Hospital and home Hospital and home Hospital
Spiracur | SNaP® | Hospital and home
Talley Group Limited | Venturi™ Negative Pressure Wound Therapy | Hospital and home

## Home Use of Negative Pressure Wound Therapy Compared With Other Wound Care Methods

Six studies compared NPWT with other wound care therapies (KQ 2, KQ 4).51–56 Study details are provided in evidence tables (Appendix D).

### Study Designs

Only one of the identified studies comparing NPWT with other wound care therapy was a RCT. Ford et al. randomized patients with pressure ulcers to either NPWT (n=20 ulcers) or one of three gel products (n=15 ulcers) over 6 weeks.56 The three gel products were a papain-urea debridement ointment for necrotic wounds, a cadexomer iodine product for decubitus ulcers, and a papain-urea-chlorophyllin-copper ointment for clean, granulating wounds.

The other five studies were retrospective observational studies. Lavery et al.54 identified patients on NPWT from a proprietary database (n=1135) and compared these to patients in studies from a meta-analysis (n=586) (Margolis, 2000).68 Fife et al. identified those on NPWT (n=72) and those not (n=1,299) from a proprietary medical records database from wound care centers in 18 states over 5 years.53 Lerman et al. identified and followed people on NPWT prospectively, but used a matched historical control identified through chart review, that was matched prior to reviewing outcomes.52 Schwien et al. identified patients with pressure ulcers using NPWT (n=60) and those not using NPWT (n=2,288) from a data warehouse of home health patient records.55Yao et al. identified those on NPWT (n=171) and those not (n=171) through chart review of patient records from a major medical center data warehouse.51

### Participants

In only one study were patients clearly treated in the home setting.55 The description of settings was vague in each of the other studies. We included studies that were described as in "outpatient setting" if it was reported (or we interpreted) that patients were not in assisted living, skilled or maintenance nursing homes. In two studies, (Ford, 2002; Yao, 2012)51, 56 patients were recruited in the inpatient setting but followed up in the outpatient setting. For these studies, we contacted the authors to confirm that the patients were not hospitalized during the followup period. One author (Ford) replied that we interpreted correctly that followup was conducted in the outpatient setting. The other author (Yao) did not respond to our query.

For each of the studies, there was limited information about the participants, including about each of the patient characteristics that we sought to examine (KQ4). There was also limited information about wound characteristics, such as wound age and size (KQ4).

We present the results organized by etiology of the wound. Yao et al. (2012) evaluated wound healing in patients with lower extremity ulcers of different etiologies (diabetic, arterial, pressure, venous insufficiency, and mixed ulcer).51 Two studies limited participants to those with diabetic foot and arterial ulcers (Lavery, 2007; Fife, 2008).53, 54 Two studies focused on pressure ulcers (Ford, 2002; Schwien, 2005).55, 56 One study examined NPWT in participants with mixed ulcers (Lerman, 2010).52 Table 4 lists the number of studies included for each type of chronic wound.

Table 4 Number of studies comparing NPWT with other wound care methods that evaluated each type of outcome for each type of chronic wound

Type of chronic wound | Total number of studies | Clinical outcomes | Patient-centered outcomes | Adverse events
Diabetic foot ulcers and arterial ulcers | 3 retrospective cohorts | 2 | 1 | 1
Pressure ulcers | 1 RCT 2 retrospective cohorts | 2 | 0 | 2
Venous insufficiency ulcers | 1 retrospective cohort | 1 | 0 | 0
Mixed ulcer population | 2 retrospective cohorts | 2 | 0 | 1

RCT = randomized controlled trial

### Interventions

Beyond the brand name, the specifics of the NPWT device were not described in five studies (Lavery, 2007; Yao, 2012, Fife, 2008, Lerman, 2010 and Schwien, 2005).51–55 In all but one of the studies, a Vacuum Assisted Closure (V.A.C.®) Therapy device (Kinetic Concepts, Inc., San Antonio, TX) was used. Lerman et al. used the Smart Negative Pressure (SNaP®) Wound Care System (Spiracur, Inc., Sunnyvale, CA).52 Ford et al. stated that the dressings used with the NPWT device were changed on Mondays, Wednesdays, and Fridays.56

Details about the therapy provided in the comparison group were not provided in three studies (Yao, 2012, Fife, 2008, and Schwien, 2005).51, 53, 55 In these studies, the comparison group was usually described as patients who did not receive a NPWT device or received other wound care treatment. The comparison group in Lavery et al. were those in the Margolis, 2000 meta-analysis that received wet-to-moist dressings.54 The comparison group in Lerman et al. received wound care therapies that included Apligraf® (Organogenesis, Canton, MA), Regranex® (Smith and Nephew, Inc., London, UK), and skin grafting.52 It was designed that the patients in the comparison group in Ford et al. would receive one of three gel products, depending on the type of wound.56 The three gel products were a papain-urea debridement ointment for necrotic wounds, a cadexomer iodine product for decubitus ulcers, and a papain-urea-chlorophyllin-copper ointment for clean, granulating wounds. No wounds received the papain-urea product, as they were all surgically debrided. The dressings in the comparison group were changed either once or twice daily.

### Outcomes

We sought data about 14 different outcomes categorized as clinical outcomes (five outcomes), patient-centered outcomes (three outcomes), and adverse events (six outcomes). As shown in Table 4, few outcomes were reported across the six studies. The outcomes are discussed in more detail below. However, in general, the outcomes were poorly defined, differentially reported for NPWT and control groups, and in some cases surrogate measures were used. For instance, wound measurements are essential to the evaluation of wound healing and wound healing rates. Only two studies, by Lerman et al. and Ford et al., evaluated wound dimensions by linear measurements, wound photographs, and by obtaining plaster impressions by blinded clinic staff.52, 56

### Study Quality

The Ford et al. study was the only RCT and it was judged to be of fair quality.56 This RCT had adequate randomization sequence generation, but we could not determine if there was adequate concealment of allocation. The clinic staff that performed wound measurements using plaster molds were blinded to intervention status. However, study participants were not blinded due to the nature of the study. There was incomplete reporting for some of the outcomes, such as osteomyelitis, and incomplete reporting of diabetes mellitus status and control. Lastly, the wounds of the comparison groups were heterogeneous in nature, as some required a cadexomer iodine ointment for potentially infected wound beds related to exudate characteristics while other wounds were considered “clean.”

The remaining five studies were observational studies of fair51 to poor quality.52–55 These studies had several methodological issues, including inappropriate control groups,53, 54 high attrition,52 poor outcome reporting,51, 53 the potential for data dredging as details about how the comparison group was identified were not reported,55 and poor reporting of comorbidities or concomitant treatments.51–53 Figure 3 summarizes the risk of bias for each included study.

Figure 3 Summary of the risk of bias scores for each study that compared a negative pressure wound therapy with other wound care treatment among patients with chronic wounds

The figure shows the risk of bias scores for each of the included studies that compared a NPWT device with other wound care treatment. The studies were rated on (1) random sequence generation, (2) allocation concealment, (3) blinding of participants and personnel, (4) incomplete outcome data, and (5) selective reporting. Studies were rated as having low risk, high risk, and unclear risk. The scores for Fife 2008 are high, high, high, low, and high. The scores for Ford 2002 are low, unclear, low, low, and high. The scores for Lavery 2007 are high, high, high, unclear, high. The scores for Lerman 2010 are high, high, high, high, unclear. The scores for Schwien 2005 are high, high, high, unclear, unclear. The scores for Yao 2012 are high, high, low, low, unclear.

### Effects of Interventions

#### Among Patients with Diabetic Foot Ulcers and Arterial Ulcers (3 studies)

##### Clinical Outcomes

Lavery et al. defined wound healing in the NPWT group as closure by secondary intention or by surgical intervention if adequate granulation for closure was documented. Wound healing in the control group was defined as wounds completely healed (no drainage or full epithelialization).54 The proportion of wounds achieving complete wound healing was compared at 12 and 20 weeks. The proportion of wounds reaching complete healing was statistically significantly greater in groups treated with NPWT as compared with those in the control group receiving wet-to-moist therapy when measured at 12 weeks (40% versus 24%) and 20 weeks (46% versus 33%) (P < 0.001).

Lavery et al. also examined healing in relation to ulcer size and wound duration at 12 and 20 weeks.54 Wounds were stratified according to wound size and duration. Wounds less than 2 cm^2^ were considered small, those 2 to 4 cm^2^ were medium in size, and those greater than 4 cm^2^ were considered large in size. Wounds that were less than 6 months old were stratified as short duration, those 6 to 12 months old were considered medium duration, and those greater than 12 months old were considered long duration.

The authors reported that wounds of all sizes treated with NPWT were more likely to achieve successful treatment endpoint (closure through secondary intention or through surgical intervention, or if adequate granulation tissue was present) (P < 0.05). However, at 12 weeks, wounds in the NPWT group that were less than 6 months duration and those greater than 12 months duration were more likely to achieve closure. At 20 weeks, NPWT healed significantly more wounds only among wounds older than 12 months (P < 0.05).54

Yao et al. analyzed complete healing as an event but did not define complete healing.51 Those using NPWT were more likely to achieve wound closure than the those in the control group for both patients with diabetic foot ulcers and arterial ulcers. After adjustment for co-morbidities (including diabetes, peripheral arterial disease, coronary heart disease, chronic kidney disease, congestive heart failure, stroke, smoking) and “other variables associated with disease severity” (undefined), those treated with NPWT had a higher incidence of wound closure compared to the control group among patients with diabetic foot ulcers (adjusted hazard ratio 3.26 (95% confidence interval [CI], 2.21 to 4.83)) and among patients with arterial ulcers (2.27 (95% CI, 1.56 to 3.78)).

None of the studies reported on other clinical outcomes such as time to complete wound healing by secondary intention, time to surgical readiness, or mortality.

##### Patient-Centered Outcomes

Fife et al. reported no differences in the provision of pain medication between the NPWT and non-NPWT groups (data not reported).53 None of the other studies reported pain as an outcome and no study reported other patient-centered outcomes, such as functional activity or quality of life.

##### Adverse Events

Fife et al. reported that patients in the NPWT group compared with those in the control group had fewer infections as indicated by the surrogate measures of fewer antibiotic prescriptions written (P < 0.05), and fewer cultures taken (P < 0.05).53 However, the authors did not report any data for these outcomes nor report the specifics of statistical testing. There were no incidences of bleeding in either group. Additionally, NPWT was not discontinued because of bleeding. The other two studies that included patients with diabetic foot ulcers and arterial ulcers did not report adverse event outcomes.

#### Among Patients with Pressure Ulcers (3 studies)

##### Clinical Outcomes

In the Ford et al. study, six ulcers in the NPWT group (30%) and six ulcers in the control group (40%) underwent flap surgery.56 Two ulcers in each group completely healed (risk difference 3%, 95% CI, −18% to 25%).

Yao et al. reported that those treated with NPWT had a higher incidence of wound closure compared to those in the control group. The adjusted hazard ratio for wound healing was 1.72 (95% CI, 0.43 to 6.95) in the study by Yao et al.51

##### Patient-Centered Outcomes

None of the studies reported on patient-centered outcomes.

##### Adverse Events

Two studies reported on adverse events. Ford et al. reported one patient with diabetes, hypertension, and vascular insufficiency treated with NPWT developed sepsis related to a lateral malleolar ulcer and required amputation.56 Twenty-eight patients with 41 full thickness pressure ulcers were enrolled in this trial; however, 22 patients with 35 wounds completed the trial. Although the study reported reasons for drop outs (two patients died, three were lost to followup, and one was deemed noncompliant), they do not report the number of drop outs in each treatment group.

Schwien et al. reported that none of the patients in the NPWT group required an emergent care visit for a wound problem while 189 (8%) of the control group did (P < 0.01).55 Three patients (5%) using NPWT for their stage three or four pressure ulcer experienced hospitalizations for a wound problem versus 310 patients (14%) in control group (P < 0.05). The results remained statistically significant when data were stratified by pressure ulcer grade.

#### Among Patients with Venous Insufficiency Ulcers (1 study)

##### Clinical Outcomes

One study (Yao, 2012), compared NPWT with a control group among patients with venous insufficiency ulcers.51 In this study, wounds treated with NPWT had a higher incidence of wound closure than those not treated with NPWT among patients with venous insufficiency ulcers (adjusted hazard ratio, 6.31; 95% CI, 1.49 to 26.6).

##### Patient-Centered Outcomes

This study did not report on patient-centered outcomes.

##### Adverse Events

This study did not report on adverse events.

#### Among Patients with Mixed Ulcer Population (2 studies)

##### Clinical Outcomes

Yao et al. included patients with different ulcers of the lower extremities (diabetic foot ulcers, arterial ulcers, venous insufficiency ulcers, and pressure ulcers) and reported that all ulcers treated with NPWT had a greater chance of healing first compared with those in the control group (adjusted hazard ratio for all ulcers 2.63 (95% CI, 1.87 to 3.70)).51

Yao et al. also evaluated whether the timing of NPWT application had an effect on healing. The authors defined ulcer onset as the date the ulcer was first documented in a clinic note. Early NPWT use was defined as receiving NPWT within 3 months of ulcer onset, intermediate NPWT use was defined as receiving NPWT within 4–12 months of ulcer onset, and late NPWT was defined as receiving NPWT 1 year or later after ulcer onset. The ulcers in the early NPWT treatment group had higher incidence of wound closure compared with those in which NPWT was used later (adjusted hazard ratio 3.38; 95% CI, 1.68 to 6.82).

Lerman et al. conducted a Kaplan-Meier analysis to estimate wound healing and time to complete wound healing. Kaplan-Meier estimates of wound healing at 1, 2, 3, and 4 months was greater in the NPWT group than in the retrospective matched control group.52 The percent of wounds healed at 1, 2, 3, and 4 months was 0%, 20%, 66%, and 83% in the NWPT group and 0%, 7%, 21%, and 36% in the matched control group. Wounds in the NPWT arm had a significantly reduced time to complete healing compared with the retrospective matched control arm resulting in a 50 percent absolute reduction in time to healing (P < 0.0001).52

##### Patient-Centered Outcomes

Neither study (Yao, 2012; Lerman, 2010) reported any patient-centered outcomes.

##### Adverse Events

Lerman et al. followed patients on NPWT for 13 months and reported that 21 of 35 patients completed the study.52 Two subjects were removed due to hospitalizations not related to the wound and six subjects were noncompliant with the protocol. Seven subjects had complications related to the study protocol requiring withdrawal: allergic skin reaction to the hydrocolloid dressing (1), wound infection (1), bleeding post debridement (1), worsening lower extremity edema (1), and maceration to periwound skin (3). Data were not reported for the matched historical control group. Yao et al. did not report adverse events.

### Strength of Evidence

The strength of the body of evidence comparing NPWT with other wound care treatments (KQ2 and KQ4) is summarized in Table 5. We had pre-defined critical outcomes, those essential for decision making in wound care, for which we determined the strength of evidence. For each of these five critical outcomes, across all wound etiologies, the strength of the evidence is insufficient to draw conclusions on the effectiveness and safety of NPWT compared with other wound care treatments. There were few studies addressing each outcome for each wound etiology; for several outcomes, we identified no studies.

Most of the studies were observational studies of poor quality. Only one study was a RCT and it was judged to be fair quality.56 We downgraded the strength of evidence domain of directness because some studies used inappropriate control groups53, 54 or used surrogate markers for outcomes.53 We were rarely able to evaluate consistency. There were not enough studies to use funnel plots to determine if there was reporting bias. However, this seems to be a field where publication bias may be of concern. Five of the studies reported funding from industry, while Yao et al. did not report funding source. The RCT had a small sample size, and therefore, imprecise results.56 Some of the observational studies reported limited data on outcomes, so we were unable to determine precision.52, 53

Table 5 Negative pressure wound therapy versus other wound therapies for the treatment of chronic wounds: Strength of evidence domains

Population | Outcome | Study design: No. studies (N) | Study limitations | Directness | Consistency | Precision | Reporting bias | Strength of evidence
Diabetic foot ulcers/arterial ulcers | Complete wound healing | Observational: 2 (1979)51, 54 | High | Indirect | Consistent | Precise | Undetected | Insufficient
Diabetic foot ulcers/arterial ulcers | Time to surgical readiness | 0 | NA | NA | Unknown | NA | NA | Insufficient
Diabetic foot ulcers/arterial ulcers | Pain | Observational: 1 (1331)53 | High | Indirect | Unknown | Unable to determine | Undetected | Insufficient
Diabetic foot ulcers/arterial ulcers | Infection | Observational: 1 (1331)53 | High | Indirect | Unknown | Unable to determine | Undetected | Insufficient
Diabetic foot ulcers/arterial ulcers | Dropout rates | 0 | NA | NA | Unknown | NA | NA | Insufficient
Pressure ulcers | Complete wound healing | RCT: 1 (35)56 Observational: 1 (40)51 | Medium | Direct | Inconsistent | Imprecise | Undetected | Insufficient
Pressure ulcers | Time to surgical readiness | 0 | NA | NA | Unknown | NA | NA | Insufficient
Pressure ulcers | Pain | 0 | NA | NA | Unknown | NA | NA | Insufficient
Pressure ulcers | Infection | RCT: 1 (35)56 | Medium | Direct | Unknown | Imprecise | Undetected | Insufficient
Pressure ulcers | Dropout rates | 0 | NA | NA | Unknown | NA | NA | Insufficient
Venous insufficiency ulcers | Complete wound healing | Observational: 1 (33)51 | High | Direct | Unknown | Imprecise | Undetected | Insufficient
Venous insufficiency ulcers | Time to surgical readiness | 0 | NA | NA | Unknown | NA | NA | Insufficient
Venous insufficiency ulcers | Pain | 0 | NA | NA | Unknown | NA | NA | Insufficient
Venous insufficiency ulcers | Infection | 0 | NA | NA | Unknown | NA | NA | Insufficient
Venous insufficiency ulcers | Dropout rates | 0 | NA | NA | Unknown | NA | NA | Insufficient
Mixed ulcer population | Complete wound healing | Observational: 2 (527)51, 52 | High | Direct | Consistent | Precise | Undetected | Insufficient
Mixed ulcer population | Time to surgical readiness | 0 | NA | NA | Unknown | NA | NA | Insufficient
Mixed ulcer population | Pain | 0 | NA | NA | Unknown | NA | NA | Insufficient
Mixed ulcer population | Infection | 0 | NA | NA | Unknown | NA | NA | Insufficient
Mixed ulcer population | Dropout rates | Observational: 1 (36)52 | High | Direct | Unknown | Unable to determine | Undetected | Insufficient

NA = not applicable; RCT = randomized controlled trial

## Wound Care Modalities Used Prior To Or With Intervention

We attempted to abstract and consider the potential impact of wound care therapies used prior to or with intervention in the NPWT group (Key Question 2b) and in the control groups (Key Question 2c) for each of the studies that compared home use of NPWT with other wound care therapies. We also attempted to consider how these prior and concurrent therapies compare with the usual care of chronic wounds (Key Question 2d). However, the six studies addressing NPWT versus other chronic wound care therapies did not discuss specific wound care regimens used prior to or concurrently with NPWT. Instead, nondescript terms such as “complete wound therapy program” or “traditional treatments” were used to define wound care modalities prior to NPWT initiation in some studies.52, 54 One study, by Schwien et al., described the use of “any other wound care therapy” as inclusion criterion for the comparison group.55 Most studies mentioned debridement of necrotic tissue as part of their inclusion criteria or pretreatment modalities.51, 52, 54, 56

Strict diabetes management and compression therapy for venous ulcers are other important factors in wound healing. Unfortunately, this parameter was not consistently reported, even in studies evaluating healing specific to these wounds. “Comprehensive diabetes management” was an inclusion criterion for the NPWT group only in one study (Lavery, 2007).54 Pressure reduction of diabetic foot ulcers and pressure ulcers is mentioned in the treatment and control groups of two studies (Lavery, 2007 and Ford, 2002).54, 56

In the Ford et al. trial, pretreatment in a pressure ulcer trial included tissue and/or bone cultures plus magnetic resonance imaging (MRI) for suspected osteomyelitis and a 6-week course of antibiotics for confirmed osteomyelitis in the treatment and control groups.56 Pretreatment tests were repeated at the conclusion of the trial.

Specific reference to the use of “appropriate beds” and repositioning throughout the treatment period was mentioned in the Lavery et al. study evaluating NPWT in stage three and four pressure ulcers, while “reduction in pressure of the affected ulcer, as needed,” and “appropriate offloading, as needed,” was mentioned by Ford et al. “Wet-to-moist dressings” were the treatment used in the control group of the Lavery et al. study.54

## Characteristics of Negative Pressure Wound Therapy Compared With Other Characteristics

We identified one study which compared two different NPWT technologies (Key Question 3). The study was reported in two articles: one article, by Armstrong et al., 2011,^57^ reported interim analysis of results, while the second, by Armstrong et al., 2012,^58^ was the final report. Study details are provided in evidence tables (Appendix D).

### Study Design

Participants were randomized to two types of technologies, the Vacuum Assisted Closure (V.A.C.) Therapy System, marketed by KCI (n=68), and the Smart Negative Pressure Wound Care System (SNaP), marketed by Spiracur (n=64). Patients were evaluated at 4, 8, 12, and 16 weeks.

### Participants

Patients with either diabetic foot ulcers or venous insufficiency ulcers were enrolled in the outpatient setting. (As noted earlier, we included studies that were described as in "outpatient setting" if it was reported (or we interpreted) that patients were not in assisted living, skilled or maintenance nursing homes.) Patients were excluded if they were under 18 years of age, if their ulcer size was less than 1 cm^2^ or greater than 100 cm^2^, if there was any clinical sign of active infection as decided upon by the authors, if the ankle/brachial index was less than 0.7 or greater than 1.2, if the wound was greater than 10 cm in the widest diameter, or if the wound was not present for at least 30 days despite appropriate wound care prior to entry. Though the number enrolled and mean age were fairly similar, there appears to be a difference in the mean size of the wound, with the V.A.C. group being used on a larger wound size (9.85 versus 5.37 mean cm^2^).

### Interventions

The V.A.C. system uses an electric powered pump device, which is re-used, and disposable dressings. Two models of V.A.C. were used: the ActiV.A.C. system and the Freedom V.A.C.. Of the V.A.C. group, 94.6 percent were on the ActiV.A.C. system, with the remaining 5.4 percent placed on the Freedom V.A.C.. The SNaP system is designed to be disposable in its entirety. The negative pressure is generated by a mechanical force, without electricity.

Characteristics of the devices that may play into wound healing such as suction pressure, and the details regarding the two devices were not described in this study (Table 6). Both devices were designed to be portable, however, the dressing type is variable between the two groups. No difference in characteristics between the two V.A.C. devices used was mentioned.

Negative pressure (suction) parameters were not reported. No irrigation/instillation components were reported. There is a description of the time it takes to apply the device in the clinic, however, it is unclear as to who is applying the device to the wound. It may be inferred that the device was placed by the study staff.

Table 6 Characteristics of the negative pressure wound therapy devices used in the randomized controlled trial

Author, year | Group | Suction type | Dressing type^*^ | Pressure control | Portable | Reusable
Armstrong, 2012^58^ | SNaP | Continuous | Gauze | Continuous | Yes | Single use
Armstrong, 2012^58^ | V.A.C. | Not reported | Foam | Not reported | Yes | Not reported

* Dressing type was reported in the interim analysis publication.57

SNaP = Smart Negative Pressure Wound Care System; V.A.C. = Vacuum Assisted Closure Therapy System

### Outcomes

Complete wound healing was a secondary outcome in this study but the outcome was not defined. Adverse events and patient-centered outcomes were assessed. Details about the outcomes are discussed below.

### Study Quality

The overall study quality for this RCT was rated as fair. There was adequate random sequence generation and allocation concealment, but participants and study personnel were not blinded (Figure 4).

There were some additional problems with study quality. Some of the baseline characteristics may affect the study, such as the difference in wound size between the two groups. This may have an impact on full healing, and healing rates to full closure are not discussed. A larger wound may take longer to heal by the nature of the size of the wound. In addition, there are a number of differences between the devices themselves, such as the difference in dressing type (gauze versus foam). The limitation to two specific types of chronic wounds does provide some level of standardization. However, the comparator group utilized two different V.A.C. systems. The number of patients is also small. The assessment of pain level is unclear, as there is a comparison to an expected sum. The use of exit interviews, given that the devices could not be adequately blinded, may have introduced bias in the patient-reported outcomes.

Figure 4 Summary of the risk of bias scores for the study that compared a negative pressure wound therapy device with another negative pressure wound therapy device among patients with chronic wounds

The figure shows the risk of bias scores for each of the included studies that compared two different NPWT devices. The studies were rated on (1) random sequence generation, (2) allocation concealment, (3) blinding of participants and personnel, (4) incomplete outcome data, and (5) selective reporting. Studies were rated as having low risk, high risk, and unclear risk. The scores for Armstrong 2011 are low, low, high, high, low.

### Effects of Interventions

#### Clinical Outcomes

The percentage of wounds closed at 4, 8, 12, and 16 weeks was assessed. The percent of wounds healed did not differ significantly between the two different NPWT devices (Kaplan-Meier estimates Wilcoxon P= 0.9252).58 Time to surgical readiness of the wound bed and mortality were not reported. Though percent decrease in the wound area was reported, the wound healing rate for healed wounds was not reported. The proportion of wounds healed appears to be similar between the two groups, however, the different V.A.C. devices were not further separated into subgroups.

#### Patient-Centered Outcomes

Exit surveys to assess user experiences were completed for the 105 of the subjects who finished the study (n=52 V.A.C. and N=53 SNaP). To examine the ability to return to their prior level of functional activity, subjects were asked about their level of activity both during and after device usage. Patients who were treated with the SNaP device were significantly more likely to agree or strongly agree that they were able to perform their normal daily activities than patients treated with the V.A.C. device (79% versus 58%; P = 0.004 *calculated by review authors).58 Additionally, a higher percentage of SNaP-treated subjects than V.A.C.-treated subjects reported that their activity level either increased or stayed the same (83% versus 48%; P < 0.05 *calculated by review authors).

The level of pain was examined in the exit interviews, by a summation of pain scores, as compared to what would be the expected sum of scores. It is unclear how the expected score number was obtained, and further description of the definition of the pain scores is not described. Patient-reported pain scores were not statistically significantly different between the two NPWT devices.58

Health-related quality of life was not assessed.

#### Adverse Events

The number of patients who were diagnosed with an active infection while using the devices was five in the V.A.C. group, and two in the SNaP group (7.4 % versus 3.1%, P = 0.28* calculated by review authors). Other adverse events including amputation rates, emergency room visits, unplanned hospitalizations/surgeries, and blood transfusions/bleeding were not reported. Of the 132 patients enrolled, 14 subjects were dropped prior to initiation of treatment, and an additional three subjects dropped after baseline, prior to follow up assessments. Eighty-three patients completed the study with healing or for the full 16 weeks of therapy. Reasons for dropout were not reported.

### Strength of Evidence

The grading of the strength of evidence of the body of literature comparing different characteristics of NPWT technologies is summarized in Table 7. We determined that the evidence was insufficient to make any conclusions about the effect of characteristics of NPWT on chronic wound care.

We found a single RCT of fair quality that compared two different NPWT devices among patients with diabetic foot ulcers and venous insufficiency ulcers. This RCT reported on complete wound healing, pain, infections, and dropout rates. We did not find any studies that evaluated different NPWT characteristics in terms of time to surgical readiness. We rated the study as having a medium level of study limitations because of lack of blinding, imbalanced study groups particularly in terms of wound size, and lack of reporting of intervention details. We downgraded study limitations to “high” for the outcome of pain because of limited reporting of statistical details. All of the outcomes were direct, but the results were imprecise. We were unable to assess consistency or reporting bias. The study was funded by the manufacturer of one of the devices (SNaP) and two of the investigators reported receiving funding from manufacturers of both devices being evaluated.

Table 7 Characteristics of negative pressure wound therapy versus other characteristics for the treatment of chronic wounds: Strength of evidence domains

Outcome | Study design: No. studies (N) | Study limitations | Directness | Consistency | Precision | Reporting bias | Strength of evidence
Complete wound healing | RCT: 1 (132)57, 58 | Medium | Direct | Unknown | Imprecise | Undetected | Insufficient
Time to surgical readiness | 0 | NA | NA | Unknown | NA | NA | Insufficient
Pain | RCT: 1 (105)57, 58 | High | Direct | Unknown | Imprecise | Undetected | Insufficient
Infection | RCT: 1 (132)57, 58 | Medium | Direct | Unknown | Imprecise | Undetected | Insufficient
Dropout rates | RCT: 1 (132)57, 58 | Medium | Direct | Unknown | Imprecise | Undetected | Insufficient

NA = not applicable; RCT = randomized controlled trial