# Methods

The Agency for Healthcare Research and Quality (AHRQ) and the Center for Medicare and Medicaid Services (CMS) commissioned the Johns Hopkins University Evidence-based Practice Center to conduct a systematic review on the effectiveness and safety of negative pressure wound therapy (NPWT) for chronic wound care compared with other wound care treatments or other NPWT devices in the home setting.

For KQ1 (the list of NPWT used to treat patients with chronic wounds) we searched the U.S. Food and Drug Administration’s Web site for NPWT currently approved for use in the U.S. We supplemented this list by searching manufacturer’s Web sites and reviewing the previous technology assessment on NPWT.31 The following methods refer to KQs 2 through 4.

## Protocol Development

Representatives from the Coverage and Analysis Group (CAG) at CMS posed the questions for the review. We drafted a protocol for preparing this systematic review. With feedback from the AHRQ and CAG representatives, we finalized the protocol and registered it on PROSPERO (CRD42014008909).

## Search Strategy

In June 2014, we searched the following databases for primary studies: MEDLINE®, Embase®, the Cochrane Central Register of Controlled Trials, and the Cumulative Index to Nursing and Allied Health Literature (CINAHL®). We developed a search strategy for MEDLINE, accessed via PubMed®, based on an analysis of medical subject headings (MeSH) and text words of key articles identified a priori. We had no date or language restrictions in the search strategies, and we hand searched the reference lists of included articles and relevant reviews. Additionally, in March 2014, we searched Clinicaltrials.gov to identify any relevant registered trials. Our search strategies are presented in Appendix A.

## Study Selection

Two independent reviewers screened each abstract (see Appendix B). Both reviewers had to agree that the article met at least one of the exclusion criteria to be excluded (see Table 1 for the list of inclusion/exclusion criteria developed a priori and outlined in our protocol). We tracked and resolved differences between reviewers regarding abstract inclusion or exclusion through consensus adjudication.

Articles promoted on the basis of the abstract screen underwent another independent screen by two reviewers using the full-text (see Appendix B for article review form). We tracked and resolved differences between reviewers regarding article inclusion or exclusion through consensus adjudication.

We included studies that evaluated patients with chronic wounds. We considered chronic wounds to be venous insufficiency ulcers, arterial ulcers, diabetic foot ulcers, or ulcers of a mixed etiology. Chronic wounds were defined by the type of wound, without any restrictions on the duration of the wound. We excluded studies of patients with surgical or traumatic wounds. We also excluded studies that included fewer than 20 patients with chronic wounds as studies with 10 or fewer patients per group were considered to not be adequately powered to detect meaningful differences for the clinical outcomes of interest. We considered studies eligible regardless of whether the population was a Medicare population (i.e., 65 years of age or older; disabled).

We included studies that evaluated a NPWT device commercially available and approved for use in the U.S. We included studies that compared a NPWT device with other wound care methods or with another NPWT device. We considered eligible studies with independent and paired comparison groups.

We included studies that evaluated clinical outcomes (complete wound healing, time to complete wound healing, time to surgical readiness of the wound bed, mortality, or wound healing rate for healed wounds), patient-centered outcomes (return to prior level of functional activity, pain, or health-related quality of life), or adverse events (infection rates, extremity amputation, emergency room visits related to the NPWT or treated wound, unplanned hospitalizations/surgeries related to the NPWT or treated wound, blood transfusions/bleeding, or dropout rates and the reasons for dropout). Generally, closure of the surface of the wound by the growth of epithelium over the defect is healing. If the closure has durability over time it is complete wound healing. Complete wound healing was considered as defined by the study authors and we included their definitions, when provided. We did not include the surrogate outcome wound healing rate (percent ulcer area reduction or other measurement) as an outcome for unhealed wounds. Chronic wounds may not heal in a linear fashion, becoming static at any time, and thus rate cannot be used to accurately predict complete healing.48

We focused our review on studies that followed patients in the home setting. We included studies that were described as in "outpatient setting" if it was reported (or we interpreted) that patients were not in assisted living, skilled or maintenance nursing homes.

Table 1 Inclusion and exclusion criteria

PICOTS | Inclusion criteria | Exclusion criteria
Population and condition of interest | - We included studies of human subjects.; - We included studies of patients with chronic wounds of any etiology (venous, arterial, diabetic, pressure, or mixed).; - We included studies with any population regardless of age or disability. | - We excluded studies of patients with surgical or traumatic wounds.
Interventions | - We included studies of NPWT. | - We excluded studies that did not evaluate an NPWT that is commercially available and approved for use in the U.S.
Comparisons | - We included studies that compared NPWT with other wound care methods.; - We included studies that have a comparison group. Comparison groups could be either independent or paired. | - We excluded studies that did not have a comparison group.
Outcomes | - We included studies that evaluated one of the following outcomes:; - Clinical outcomes; - Complete wound healing; - Time to complete wound healing; - Time to surgical readiness of the wound bed; - Mortality; - Wound healing rate for healed wounds; - Patient-centered outcomes; - Return to prior level of functional activity; - Pain; - Health-related quality of life; - Adverse events; - Infection rates; - Extremity amputation; - Emergency room visits related to the NPWT or treated wound; - Unplanned hospitalizations/ unplanned surgeries related to the NPWT or treated wound; - Blood transfusions/bleeding; - Dropout rate of patients and reasons | - We excluded studies that reported wound healing rates without also reporting complete wound healing.
Type of study | - Any study design with a comparison group was eligible. | - We excluded articles with no original data (e.g., reviews, editorials, and commentaries).; - We excluded studies with less than 20 subjects.; - We excluded studies published in languages other than English.; - We excluded meeting or conference abstracts.
Timing and setting | - We included studies regardless of the length of followup.; - We included studies that are conducted in the home. (We included studies that were described as in "outpatient setting" if it was reported (or we interpreted) that patients were not in assisted living, skilled or maintenance nursing homes.) | - We excluded studies conducted in the hospital, inpatient, or long-term care settings.

NPWT = negative pressure wound therapy

## Data Extraction

We created and pilot tested standardized forms for data abstraction (see Appendix B). Each article underwent double data extraction by the study investigators. The second reviewer confirmed the first reviewer’s abstracted data for completeness and accuracy. Reviewer pairs were formed to include personnel with both clinical and methodological expertise. For all articles, the reviewers extracted information on general study characteristics (e.g., study design, study period, and followup), study participants (e.g., age, sex, smoking status, vascular status, glycemic control, wound etiology), characteristics of the wound (e.g., location, age, size, infection status, and quantity), interventions (e.g., negative pressure parameters, wound dressing types, type of pressure control [continuous, intermittent, or dynamic], portable or stationary units, irrigation or instillation components), comparisons, outcome measures, definitions, and the results of each outcome, including measures of variability.

We also collected data on treatments used prior to NPWT, whether debridement was conducted prior to NPWT, and the manner in which complete wound healing was classified and confirmed. We collected data on subgroups of interest (e.g., wound location, wound age, wound size, wound infection, number of wounds, age, sex, comorbidities, nutritional status, smoking status, vascular status, glycemic control, prior treatments, and wound etiology).

All information from the data extraction process was entered into the Systematic Review Data Repository (SRDR) database (Systematic Review Data Repository. Accessed at http://srdr.ahrq.gov/ on February 20, 2014) by the individual completing the review. Reviewers entered comments into the system whenever applicable. The SRDR database was used to maintain the data and to create detailed evidence tables and summary tables.

## Quality (Risk of Bias) Assessment of Individual Studies

Two reviewers independently assessed individual study quality. We used the Cochrane Collaboration’s Risk of Bias Tool49 to assess the quality of all included studies. For both the RCTs and the nonrandomized studies, the overall study quality was assessed as good, fair, or poor.

Differences between reviewers were resolved through consensus adjudication.

## Data Synthesis

Because the different chronic wound populations are not homogenous, we synthesized the results for each wound type separately when possible.

We planned to conduct meta-analyses for an outcome if there were sufficient data (at least three studies) and studies were sufficiently homogenous with respect to key variables (population characteristics, study duration, and treatment (see protocol for planned analyses).

For the randomized controlled trials, we calculated absolute risk differences with 95 percent confidence intervals for the outcome of complete wound healing using STATA 12.1 (College Station, Texas).

We qualitatively synthesized studies, and we summarized the study design and patient population characteristics, including descriptors of the wound (e.g., wound location, age, size, infection status, etiology, and number of wounds).

## Strength of the Body of Evidence

At the completion of our review, at least two reviewers independently assigned evidence grades based on the study limitations, directness, consistency, precision, and reporting bias of the evidence body. Conflicts were resolved through consensus or third-party adjudication. We graded the strength of evidence addressing KQs 2 through 4 using the evidence grading scheme recommended in the Methods Guide.50 We applied evidence grades to the bodies of evidence about each intervention comparison for the outcomes determined to be most important in making decisions about use of this therapy. We graded the following outcomes: complete wound healing, time to surgical readiness, pain, infection rates, and dropout rate of patients and reasons.

We classified evidence pertaining to the KQs into four basic categories: 1) “high” grade; 2) “moderate” grade; 3) “low” grade; and 4) “insufficient” grade. Table 2 defines each strength of evidence grade.

Table 2 Strength of evidence grades and definitions

Grade | Definition
High | We are very confident that the estimate of effect lies close to the true effect for this outcome. The body of evidence has few or no deficiencies. We believe that the findings are stable.
Moderate | We are moderately confident that the estimate of effect lies close to the true effect for this outcome. The body of evidence has some deficiencies. We believe that the findings are likely to be stable, but some doubt remains.
Low | We have limited confidence that the estimate of effect lies close to the true effect for this outcome. The body of evidence has major or numerous deficiencies (or both). We believe that additional evidence is needed before concluding either that the findings are stable or that the estimate of effect is close to the true effect.
Insufficient | We have no evidence, we are unable to estimate an effect, or we have no confidence in the estimate of effect for this outcome. No evidence is available or the body of evidence has unacceptable deficiencies, precluding judgment.

## Applicability

We assessed the applicability of studies in terms of the degree to which the study population (age, duration of ulcer, comorbidities), interventions (treatment, cointerventions, duration of treatment), and outcomes may be applicable for the treatment of individuals with chronic wounds who are treated with NPWT in the home setting. We also specifically considered and discussed applicability of the evidence to the Medicare population.

## Peer Review and Public Commentary

Experts in wound care, dermatology, endocrinology, geriatrics, internal medicine, nursing, plastic surgery, podiatry, and vascular surgery, and representatives from other government agencies were invited to provide external peer review of this Technology Assessment; AHRQ and CAG representatives also provided comments. The draft report was posted on the AHRQ Web site for 3 weeks to allow for public comment. We addressed all reviewer comments, revising the text as appropriate, and documented everything in a “disposition of comments report” that will be made available 3 months after the Agency posts the final Technology Assessment on the AHRQ Web site.