# Introduction

Chronic wounds are wounds that have failed to proceed through the normal process of healing.1 There are varying etiologies of chronic wounds in the U.S. population, which all create a burden upon the health care system. The health care expenditures for chronic wounds have been estimated to be up to $25 billion dollars per year.2, 3

Common types of chronic wounds include venous insufficiency ulcers, arterial leg ulcers, diabetic foot ulcers, and pressure ulcers.4 These wounds can affect a large number of people with varying degrees of severity. Venous insufficiency ulcers are a large proportion of chronic wounds as a whole, with over 50% of chronic leg ulcers occurring as a result of a venous etiology.5 Amputations related to diabetic foot wounds have been associated with high cumulative mortality – up to 70 percent within 10 years from the first amputation due to a diabetic foot ulcer.6 Annual prevalence of venous insufficiency ulcers in those 65 and older has been estimated to be 1.69 per 100 person-years.7 The prevalence of pressure ulcers varies between 0.31 to 0.70 percent per year, with increasing incidence with advancing age.8 Given the aging population in the United States and the growing incidence of cardiovascular disease, diabetes, and obesity,9, 10 the prevalence of chronic wounds, and the associated burdens, can only be expected to grow.

There are a variety of modalities available for chronic wound treatment, with some targeted toward specific types of wounds, such as compression for venous insufficiency ulcers. Routine wound care may involve any or all of the following: debridement (removal of material from the wound bed to permit healing), wound dressings (including gauzes, films, hydrogels, hydrocolloids, alginates, and foams), barrier products, and topical or systemic antimicrobials. In addition to these various wound dressings and medications, there are other adjunctive treatment modalities, such as skin substitutes, hyperbaric oxygen, and negative pressure wound therapy (NPWT).4 This last modality is the focus of our review.

NPWT refers to the application of negative pressure across a wound. The technology emerged in the 1980s11 and consists of the application of a dressing, usually foam or gauze, on the wound, which is then connected through tubing to a vacuum pump. The area is sealed with an adhesive film and the pump delivers a controlled negative pressure across the wound bed.12 The Centers for Medicare and Medicaid Services (CMS) defines NPWT as the “application of subatmospheric pressure to a wound to remove exudate and debris, via an integrated system consisting of a suction pump, separate exudate collection chamber, and dressing, over specific wounds”.13 The aim of NPWT is to facilitate wound healing, promote granulation of the wound bed, and provide a bridge to surgical closure.

There are many mechanisms by which these devices may promote wound healing. Mechanisms of action include removing excess fluid while improving circulation to the wound bed,14 reducing bacterial load on the wound surface, providing a mechanical effect that aids wound healing,15 promoting cell proliferation and synthesis,16, 17 and increasing the level of angiogenic and stimulatory cytokines,18 and endothelial cell mobilization.19–22

With the potential benefits, there are also potential harms associated with NPWT. Reported adverse effects include pain, retention of foreign bodies from the dressing, bleeding, infection, death from infection or bleeding, and even complications stemming from power outages, which results in unrecognized interruption of therapy.23–29 In 2011, the U.S. Food and Drug Administration (FDA) issued a safety communication regarding serious complications associated with NPWT systems. Their report included 174 reports of injury and 12 deaths that have occurred since 2007. Of significant concern was the number of events happening in the home setting. Infection was the most common; however, bleeding was the most severe adverse event, and it led to significant morbidity and mortality. As a result, the FDA issued recommendations regarding patient selection, monitoring, contraindications, and risk factors that should be followed by clinicians. Additionally, the FDA endorsed education of the patient and caregivers to improve safety monitoring in the home setting.30

The devices range in price and in type; many different devices are available, and each offers a variety of options, including the ability to: add instillation fluids, vary the negative pressure settings, vary the dressing applied to the wound base from foams to gauzes, and use multiple types of overlying wound dressings. In traditional systems the electronic pump is continually used and the dressings are disposable. There are also systems where both the pump and dressings are disposable.

NPWT devices are usually applied by a variety of clinicians, but patients can apply some of the newer technologies. A number of manufacturers produce these devices, though the majority of the devices used in the U.S. come from just a few vendors.31

The NPWT technology has been widely adopted for the management of surgical wounds, especially those which need to heal by secondary intention. NPWT devices are marketed for wounds such as open abdominal incisions, dehisced surgical wounds, burns, preparation for skin graft sites, and traumatic wounds.32–36

In addition to treatment of acute surgical wounds, NPWT has been used to treat multiple types of chronic wounds (i.e., wounds that have failed to heal, or those that do not respond to treatment). These types of wounds are typically managed in the home or outpatient setting, or nonacute care facilities such as rehabilitation or skilled nursing units.

The common chronic wounds treated with NPWT are those referenced above: venous insufficiency ulcers, diabetic foot ulcers, and pressure ulcers.23, 37–42 It is in these chronic nonhealing wounds for which further evaluation of the efficacy of NPWT in the home environment is needed.23, 43–45

Due to a lack of studies, results from previous systematic reviews of NPWT have primarily illustrated limitations in the evidence.31, 37, 46, 47 For example, a Technology Assessment completed in 2009 supported by the Agency for Healthcare Research and Quality (AHRQ) demonstrated a lack of well-designed comparative studies assessing NPWT for a variety of different types of wounds.31 In addition, none of these prior reviews examined the use of NPWT specifically in the home environment.

There is a critical need for evidence to guide the appropriate use of NPWT, particularly due to the increase in incidence of chronic wounds, driven by the aging of the U.S. population, as well as by increases in incidence of diabetes and obesity, all risk factors for developing chronic lower extremity wounds.

It is critical to assess the quality and strength of evidence related to the use of NPWT for chronic wounds in the home environment, especially as it applies to the Medicare population (i.e., those over 65 years of age or with disabilities).

## Scope and Key Questions

In this systematic review, sponsored by AHRQ, we reviewed the literature on NPWT for chronic wound care in the home environment. We evaluated studies address the following Key Questions which were proposed by the Centers for Medicaid and Medicare (CMS) (Figure 1).

Key Question 1: What are the various NPWT technologies commercially available in the U.S. that are used to treat patients with chronic wounds (i.e., diabetic foot ulcers, arterial ulcers, venous ulcers, or pressure ulcers)?

Key Question 2, Part A: In patients who are similar to Medicare patients (age 65 or older or disabled) with chronic wounds, does the home use of NPWT significantly improve any of the following outcomes as compared with treatment with other wound care methods?

1. Clinical outcomes
  a. Complete wound healing by secondary intention (i.e., healing without surgical repair)
  b. Time to complete wound healing by secondary intention
  c. Time to surgical readiness of the wound bed
  d. Mortality
  e. Wound healing rate (e.g., percent ulcer area reduction or other measurement) for healed wounds
2. Patient-centered outcomes
  a. Return to prior level of functional activity
  b. Pain
  c. Health-related quality of life
3. Adverse events
  a. Infection rates
  b. Extremity amputation
  c. Emergency room visits related to the negative pressure wound therapy or treated wound
  d. Unplanned hospitalization/unplanned surgeries related to the negative pressure wound therapy or treated wound
  e. Blood transfusions/bleeding
  f. Dropout rate of patients and the reason for dropout (e.g., patients who discontinued therapy due to pain, inconvenience, lack of efficacy, another reason, or an unspecified reason)

Key Question 2, Part B: For studies included in Key Question 2, Part A, what wound care modalities were used prior to and concurrently with NPWT?

Key Question 2, Part C: For studies included in Key Question 2, Part A, what specific wound care modalities were used prior to and concurrently in the control groups of the studies?

Key Question 2, Part D: For studies included in Key Question 2, Part A, how do the treatments used prior to and/or concurrently with NPWT or the treatment of the control patients compare with usual care of chronic wounds?

Key Question 3: In patients with chronic wounds, do characteristics of the NPWT administration predict better or worse outcomes compared with other characteristics? Characteristics to be considered are:

1. Negative pressure (suction) parameters, including amplitude, frequency, duration of suction, and other parameters as specified by the device
2. Wound dressing types
3. Continuous, intermittent, or dynamic pressure control
4. Portable versus stationary units
5. Irrigation/instillation components
6. Other characteristics of NPWT administration

Key Question 4: If any answer to Key Question 2, Part A is yes, are there specific characteristics that predict better or worse outcomes? Characteristics to be considered are:

1. Wound characteristics
  a. Wound location
  b. Wound age
  c. Wound size
  d. Wound infection
  e. Number of wounds
  f. Etiology of wound
    i. Venous
    ii. Arterial
    iii. Pressure
    iv. Diabetic
    v. Mixed
  g. Other wound characteristics
2. Patient characteristics:
  a. Age
  b. Diagnosis/comorbidities (e.g., diabetes/end-stage renal disease)
  c. Nutritional status
  d. Smoking status/history
  e. Vascular status
  f. Glycemic control (as appropriate)
  g. Previous treatment applied
  h. Other patient characteristics

Figure 1 Analytic framework for the treatment of chronic wounds with NPWT in the home setting

KQ = Key Question; NPWT = negative pressure wound therapy

The figure shows an analytic framework describing key questions 2-4. Moving from left to right, there is texts, arrows with text on top, and circle that has text within and text box. The first thing on the left is, patients with chronic wounds with a main arrow pointing to the text box on the right. The text box contains clinical outcomes with bullet point listing of complete wound healing, time to complete wound healing, time to surgical readiness of the wound bed, mortality, and wound healing rate for healed wounds. In the same text box is patient-centered outcomes with bullet points listing return to prior level of functional activity, pain and health-related quality of life. On the main arrow is KQ2 NPWT vs. other wound care treatments and from it the second arrow arises, and points to the same text box as the main arrow. On top of this second arrow to the left is KQ3: Characteristics of NPWT administration with bullet point listing of negative pressure (suction) parameters, wound dressing types, continuous, intermittent, or dynamic pressure control, portable versus stationary units, irrigation/instillation components, and others. To the right is KQ 4: patients/wound characteristics with bullet point listings of wound location, wound age, wound size, wound infection, number of wounds, etiology of wound (venous, arterial, pressure, diabetic, mixed, or other), patient characteristics, and other patient/wound characteristics. There is a third arrow, branching off from underneath the main arrow, it is a curly arrow pointing to a text circle showing adverse effects with bullet points listing infection rates, extremity amputation, emergency room visits, hospitalizations/surgeries, blood transfusions/bleeding, and dropout rate of patients and the reason for dropout.