# Discussion

## Key Findings and the Strength of Evidence

- Key Question 1 did not require a systematic review, but rather a search for NPWT that are approved by the FDA for use in the United States.
- For Key Questions 2, 3, and 4, the evidence was limited and insufficient to draw conclusions regarding the use of NPWT in the home setting.
- In Key Questions 2 and 4, the comparator group was not well defined, and may or may not have included a range of wound healing modalities, all of which may or may not be beneficial for wound healing. The lack of consistency in the reporting of the various parameters important in the wound healing process made it difficult to compare the studies with one another.
- For Key Question 3, we identified only one study that compared two types of NPWT. Though the trial was randomized, the overall numbers were small. No other “outpatient only” studies were identified that compared the various components or characteristics of the devices on the market, despite the numerous devices identified in Key Question 1.

The majority of the studies showed high risk of bias across multiple areas of study design and outcomes (Figure 5), and the high risk added to the difficulty in interpreting the evidence base. We found a profound paucity of well-designed and well-conducted studies evaluating these technologies in the home setting. Though we considered studies that described following patients in the outpatient setting as studies of home use, true confirmation that NPWT was used in the home environment was lacking. The few studies we identified were either small experimental studies, or retrospective studies, which used administrative data from large databases. The studies were further limited by the lack of well-defined comparator groups. The strength of evidence for all comparisons and outcomes of interest was insufficient, which meant that we could not draw conclusions regarding the efficacy or harms associated with NPWT for chronic wounds in the home setting.

Figure 5 Risk of bias graph: review of authors' judgments about each risk of bias, presented as percentages across all included studies

The figure shows the risk of bias scores for all of the included studies. The studies were rated on (1) random sequence generation, (2) allocation concealment, (3) blinding of participants and personnel, (4) incomplete outcome data, and (5) selective reporting. Studies were rated as having low risk, high risk, and unclear risk. For random sequence generation, allocation concealment, and blinding of participants and personnel, the majority of the studies had high risk of bias. For incomplete outcome data, less than half of the studies had low risk of bias, and the rest had either high or unclear risk of bias. For selective reporting, most of the studies had high or unclear risk of bias.

## Findings in Relationship to What is Already Known

Studies on NPWT, as well as previous reviews of NPWT, either focus on surgical wounds or were performed in the inpatient setting (Tables 8 and 9). In all of the previous reviews, the same limitations in the available studies were noted. Throughout these reviews, the evidence ranged from “moderate strength” to “no valid evidence,” and the need for good quality randomized controlled trials was noted.31, 37, 47

There were two studies, which examined the use of NPWT in the care of chronic wounds, which predominantly included patients in the outpatient setting (Table 9).69, 70 However, as the outpatient data could not be analyzed separately from the inpatient data, these studies were not included in our review, given the difference in care that is provided in inpatient versus outpatient settings. Though two of the studies we included in our review recruited patients from the inpatient setting, the followup was performed in the outpatient setting, on the basis of which we considered that these subjects were not hospitalized during the followup period.51, 56 Both groups of authors were contacted to confirm, and one replied (Ford, 2002), stating that the study should be interpreted as we had interpreted it and we received no response from the other author (Yao, 2012).

Many other NPWT studies were found that did not meet our eligibility criteria. These included studies considered key in the field, which were excluded primarily because they included inpatients (Table 9).

Table 8 Summary of previous systematic reviews on NPWT

Author, year | Review scope | Setting | Number of articles | Findings
Ubbink, 2008^37^ | Effect of NPWT in chronic wound healing | Hospital | 9 (7 trials) | There is no valid or reliable evidence that NPWT increases chronic wound healing.
Sullivan, 2009^31^ | Technology assessment of NPWT devices | Inpatient and outpatient | 143 studies, 22 systematic reviews | Unable to address key questions based on the literature at that time.
Dumville, 2013^47^ | Effect of NPWT compared with standard care or adjuvant therapies in diabetic foot wounds | Any setting | 5 | There is some evidence to suggest that NPWT is more effective in healing postoperative foot wounds and ulcers of the foot in people with DM compared with moist wound dressings.
Greer, 2013^46^ | Benefits and harms of advanced wound care therapies for nonhealing diabetic, venous, and arterial ulcers | NR | 59 (56 RCTs, 3 RCTs examining NPWT) | There was moderate-strength evidence for improved healing with NPWT compared with standard care.

DM = diabetes mellitus; NPWT = negative pressure wound therapy; NR = not reported; RCT = randomized controlled trial

Table 9 Other studies found during search, representing some of the variation in the literature

Author, year | Type of study | Reason for exclusion | Findings
Argenta, 1997^71^ | Case series, clinical trial | Inclusion of subacute and acute wounds, no comparison group | Favorable response in majority of the wounds included, descriptive study.
Vuerstaek, 2006^72^ | RCT | Inpatient population only | Median time to chronic wound healing was shorter in the NPWT group versus the conventional wound care group.
Frykberg, 2007^70^ | Retrospective analysis | Mixed population of inpatient and outpatient | Amputation rates were higher in the control group versus NPWT group.
Blume, 2008^69^ | RCT | Mixed population of inpatient and outpatient | 43.2% of patients with foot ulcers closed with NPWT versus 28.9% using advanced moist wound therapy

NPWT = negative pressure wound therapy; RCT = randomized controlled trials

## Applicability

Given the mixture of wound etiologies, and the lack of details about the patients in each of the studies, it was difficult to generalize the results to the overall population. The populations studied all had chronic wounds, and since the chronic wound treatment modalities can be used across the age spectrum, the data we found could be applicable to the Medicare population. Though some of the studies identified were targeted towards a specific wound type, others were more general in their description, making it difficult to apply the results to specific populations. In addition, given the overall lack of description around what constitutes standard wound care, and the wide variety of wound care products available for standard wound care, robust comparisons could not be made. Finally, the focus of this review was use of NPWT in the home population, thus the results are not necessarily applicable to other health care settings, in which NPWT may be used.

## Limitations of the Review Process

NPWT is used to treat a variety of wounds, including acute and chronic, and is used in a variety of settings. However, our review focused specifically on the comparative effectiveness and safety of NPWT to treat chronic wounds in the home setting.

We screened 5,912 citations in our effort to find studies assessing the comparative efficacy and safety of NPWT for chronic wound care in the home or outpatient setting. While we attempted to focus on home use by using outpatient setting as an indicator of home use, many of the studies did not clearly identify the actual patient treatment location, and as a result, we could not confirm that all patients were treated in the home setting.

Only seven studies were identified as using NPWT in the outpatient setting for chronic wounds. Some studies with outcomes of interest were excluded primarily because the populations were mixed and included patients followed in the inpatient setting, which introduces a different level of care, observation, and compliance. In these mixed studies, subgroup analysis was not performed, and therefore, the outpatient subjects’ outcomes could not be defined. Wound care is performed in a variety of settings. However, given that our review focus was on the home environment, we excluded studies even if a small portion of the included subjects were followed only in the inpatient environment.

Because treatment with NPWT is often terminated prior to complete wound healing, many studies may not report on complete wound healing, but rather report on an intermediate outcome, such as the wound healing rate (e.g., percent ulcer area reduction). We excluded studies that evaluated this surrogate outcome only because chronic wounds may not heal in a linear fashion, becoming static at any time. Thus wound healing rate cannot be used to accurately predict complete healing.48

We also excluded studies with a sample size less than 20 patients. However, most of these studies were also excluded for other reasons (e.g., no original data, no comparison group, not followed in the home setting). Finally, we limited our review to studies with comparison groups. Studies of other designs, such as case series may provide further information about adverse events, but it may be difficult to interpret the cause of many adverse events without a control group.

## Limitations of the Evidence Base

There were few studies that addressed the effectiveness and safety of NPWT to treat chronic wounds in the home environment. Unfortunately, the few studies that we found were of low quality (Table 10).

The prospective, randomized studies had a small sample sizes and short durations of followup.56, 57 Larger studies were retrospective and based on administrative or patient record databases. The retrospective, administrative or patient record database studies were particularly problematic because they generally lacked details regarding patient characteristics, NPWT devices studied, treatments used by the comparison groups, and prior and concurrent wound treatments. For these studies, we were not able to establish if consistent wound care protocols were being followed. The brand and model of the NPWT device was often not reported, so we were unable to determine if there were any differences in effectiveness and safety across the devices. Similarly, there were limited details reported regarding the comparison group. Often, the control group was simply patients who did not receive NPWT.51–53, 55 Considering the wide range of treatment options for chronic wounds, we are unable to determine what treatments the comparison groups received.

Six of the seven studies were supported at least partially by manufacturers; the other study did not report a funding source.51 In the studies that reported industry funding, few reported on the involvement of the sponsor in the design, analysis, and reporting of the study. With this limited information, it is hard to rule out the possibility of publication bias or other reporting bias.

Another limitation was the use of surrogate outcomes. For instance, Fife et al. used number of antibiotic prescriptions as a surrogate measure for infections.53 However, we do not know how well antibiotic prescriptions correlate with clinical infection.

Patient-centered outcomes were frequently not reported in the studies. When they were reported, studies used either a surrogate marker, such as provision of pain medication53 or a non-validated exit interview.57, 58 Considering the burden of having chronic wounds, it is important to understand the effects of NPWT on patient-centered outcomes.

Regardless of the study design, most studies were deficient in reporting key characteristics. Many of the studies did not describe the patient setting and it was unclear who was applying the wound treatments. Furthermore, we often did not know the level of training and expertise of the people applying the wound treatment. NPWT treatments require dressing changes that must occur on a regular basis as set by the manufacturers, and thus may receive a higher level of attention from a provider, making NPWT more provider intense compared with other wound care regimens. The application of the wound treatments could affect compliance with and the effectiveness of the treatments. Compliance was not assessed in any of the studies.

Many of the studies lacked standardized descriptions of the patient population at baseline. Many patients with chronic wounds often have several comorbidities, which could affect wound healing. However, few studies reported the effect of such comorbidities on the outcomes. Some of the studies failed to report other baseline patient characteristics, such as wound duration or size. Since many of the studies were observational, it is hard to determine if patients were balanced in these key characteristics across NPWT and control groups. Therefore, we are unable to assess how selection bias could have influenced the results.

For many studies, we do not know the prior and concomitant treatments patients received. This includes not only wound care treatments, such as compression, debridement, and dressings, but also treatments to manage the underlying condition, such as diabetes management or off-loading. Due to the limited reporting, we are unable to determine how these other treatments could have influenced results.

We acknowledge that it is difficult to blind study investigators and patients in device studies. In studies where blinding is not feasible, it is important to have objective outcome assessments to minimize bias. Only one of the studies blinded outcome assessors.56 In this study, blinded staff evaluated wound healing from wound measurements of plaster impressions. Most of the other studies inadequately described how wound healing was defined and determined. The Food and Drug Administration defines complete wound healing as “skin-repithelialization without drainage at two consecutive visits, 2 weeks apart by the end of the study.”73 None of the studies used this definition.

Table 10 Characteristics of studies comparing NPWT with a control group or other NPWT devices among patients with chronic wounds

| Lerman, 2010^52^ | Ford, 2002^56^ | Schwien, 2005^55^ | Fife, 2008^53^ | Lavery, 2007^54^ | Yao, 2012^51^ | Armstrong, 2011^57^
Study Design Prospective vs. retrospective | Prospective observational, retrospective comparator group | Prospective, randomized | Retrospective | Retrospective | Retrospective | Retrospective | Prospective, randomized
Administrative data | Yes | No | Yes | Yes | Yes | Yes | No
Concurrent comparator group | No | Yes | Yes | Yes | No | Yes | Yes
Patient setting defined | Yes – Outpatient | No | Yes – Home | No | No | No | No
Description of prior wound treatment | No | No | No | No | No | No | No
Description of concurrent wound treatment | No | Yes | No | No | No | No | Yes
Clear wound outcomes definition | No | No | No | No | No | No | Yes
Use of FDA definition of complete wound healing | No | No | No | No | No | No | No
Consistent measurement protocol | Yes | Yes | No | No | No | No | Yes
Blinded outcome assessors | No | Yes | No | No | No | No | No
Identification of people applying wound therapy | No | No | No | No | No | No | No

Shaded items indicate a limitation in the study design.

FDA = Food and Drug Administration

## Research Gaps

Our findings identified multiple research gaps, the primary being a need for standardized methods in defining wound eligibility, outcome measures, and interventions. Certainly, a set protocol defining standard wound care for the various types of wounds may be helpful in designing future research protocols, and a standardized method of wound evaluation, including blinded staff and consistent methods of measurements that can be replicated in other studies, may help provide consistency and design more informative studies.

Given that patients with chronic wounds are medically complex, studies should include patients with a specific type of chronic wound and provide details about the characteristics of the wound. This would include reporting on the average number of wounds, the percent of patients with previous wounds, the size and duration of the wound, and the appearance of the wound base. The underlying medical comorbidities play a role in wound healing, thus studies need to clearly describe, and as appropriate, adjust for or provide subgroup analysis based on these characteristics. The patient cohort should be described in terms of other comorbidities using a standardized scale, such as the Charlson index. Other patient characteristics that are relevant to the underlying condition, such as hemoglobin A1c levels for patients with diabetic foot ulcers, should also be reported.

Wound care treatment is complex and future studies should provide details about the treatment protocols for both the NPWT and control groups. Careful descriptions of the care prior to and/or concurrent to NPWT or their comparison groups should be made, given the wide array of available wound care products, modalities, and adjunctive treatments. This would include details about approach to debridement, as well as concomitant treatments such as diabetes management or off-loading. For the NPWT group, details on the brand and model of NPWT, the suction parameters, wound dressing types, type of pressure control, type of units (portable or stationary), and the irrigation/instillation components should be described. Information such as the personnel performing the wound care, and the location of the treatment of the patients should be explicitly described.

Outcomes need to be clearly defined and, at a minimum, should include complete wound healing, time to surgical readiness, pain, infection rates, and dropout rate of patients and reasons. Further, outcome measurements need to be as objective as possible. Ideally, the outcome assessor(s) would be masked to treatment assignment. Several organizations, such as the FDA, and the European Wound Management Association have noted the need for objective outcomes with blinding of outcome assessors, where possible.48, 74

Larger, prospective studies are needed for each of the different types of chronic wounds treated by NPWT, and to compare the different components of these devices, if not the devices themselves. Future studies of devices need to have methodological rigor, including attention to enrollment criteria; clear definitions of outcomes that are reproducible and easily measured; the addressing of potential confounding variables; randomized designs which minimize bias; and the studies should be sufficiently powered to determine clinically important effects. Patients need to be followed for an adequate length of time to ensure sustained outcomes. Definitions for adequate follow-up and durable outcomes need to be developed. Details about what data are missing and why need to be clearly reported with appropriate methods for analysis, including intention-to-treat analysis.

In Table 11, we use the PICOS (Population, Intervention, Comparison, Outcomes, and Study design) framework to outline characteristics of an ideal study.

Table 11 Characteristics of an ideal study to compare the effectiveness and safety of negative pressure wound therapy with other wound treatments in patients with chronic wounds

PICOS | Characteristics
Population | - Includes patients with a specific type of chronic wound; - Describes the patient cohort in terms of other comorbidities using a standardized scale (e.g., Charlson index); - Describes other patient characteristics that are relevant to the underlying condition (e.g., provides information on HbA1c levels for patients with diabetic foot ulcers); - Describes baseline characteristics of the wound (e.g., number of wounds, previous ulcers, duration of wound, size of wound, size duration, and appearance of the wound base)
Intervention | - Describes a treatment protocol that the NPWT group receives, including details on the brand and model of NPWT, the suction parameters, wound dressing types, type of pressure control (continuous, intermittent, or dynamic), type of units (portable or stationary), and the irrigation/instillation components; - Details the treatments used prior to study enrollment, including the types of treatments used and the number of patients that received each treatment; - Details other concomitant treatments, such as diabetes management or off-loading
Comparisons | - Describes a treatment protocol that the comparison group receives; - Details the treatments used prior to study enrollment, including the types of treatments used and the number of patients that received each treatment; - Details other concomitant treatments, such as diabetes management or off-loading, and if debridement is used, the approach to debriding the wound
Outcomes | - Defines and uses an objective measure for complete wound healing; - Includes important outcomes, at a minimum: complete wound healing, time to surgical readiness, pain, infection rates, and dropout rate of patients and reasons; - Assesses compliance of the subject with the study intervention
Study design | - Follows patients for an adequate length of time, to ensure sustained outcomes; - Collects data on patients prospectively; - Describes the study setting, including details on who is performing the wound care, their level of training, and their expertise in applying the treatments

HbA1c = hemoglobin A1c; NPWT = negative pressure wound therapy

## Conclusion

We performed a systematic review to evaluate the efficacy and safety of NPWT for the treatment of chronic wounds in the home setting, and determined that the existing evidence is insufficient to draw any conclusions. There is a clear need for consensus on study methods, and we believe that the research community involved in NPWT devices should strive to standardize the conduct and reporting of studies, to provide stronger evidence to inform decisions about the utility and safety of these devices.