# Evidence Tables

Table 1 Study Design Characteristics of Included Studies

Author, Year | Study Design Location | Trial or Cohort Name | Funding Source | Enrollment Followup | N at Enrollment | Etiologies of Wounds | Exclusion Criteria
Armstrong, 2011^1^ | RCT United States | NR | Industry | Start year: NR End year: NR Followup: 16 weeks | 65 | Diabetic foot ulcers; venous ulcers | Age < 18 years; ulcer size < 1cm^2^; ulcer size > 100 cm^2^; clinical infection; ankle/brachial index < 0.7 or >1.2; ulcer size >10cm in widest diameter. Wounds not present for >30 days despite appropriate wound care prior to entry
Armstrong, 2012^2^ | RCT United States | NR | Industry | Start year: NR End year: NR Followup: 16 weeks | 132 | Diabetic foot ulcers; Venous ulcers | Age < 18 years; ulcer size < 1cm^2^; ulcer size > 100 cm^2^; clinical infection; ankle/brachial index < 0.7 or >1.2; ulcer size >10cm in widest diameter. Wounds not present for >30 days despite appropriate wound care prior to entry
Fife, 2008^3^ | Cohort, but the control group is a mix of pre-NPWT and never users United States | IntelliTrak | Industry | Start year: 2001 End year: 2006 Followup: NR | 1331 | Diabetic foot ulcers | Not treated in an outpatient setting
Ford, 2002^4^ | RCT United States | NR | NR | Start year: NR End year: NR Followup: 10 months | 28 | Pressure ulcers or pressure sores | Age < 21 year; Age > 80 years; ulcer duration < 4 weeks; clinical infection; comorbid conditions e.g., vasculitis, rheumatoid arthritis, severe kidney disease, heart disease; treatment with corticosteroids; absence of stage III or IV ulcers
Lavery, 2007^5^ | Cohort United States | NR | Industry | Start year: 1996 End year: 2004 Followup: NR | 2677 | Diabetic foot ulcers | No patients with chronic wounds; no debridement of necrotic tissue, no comprehensive diabetes management included with the case plan; no reduction in pressure of affected ulcer, no description of wound size and duration prior to NPWT
Lerman, 2010^6^ | Prospective observational analysis and retrospective match-controlled comparisons United States | NR | Industry | Start year: 2008 End year: 2009 Followup: 4 months | Total: 78 NPWT: 36 Control: 42 | Diabetic foot ulcers; venous ulcers | Age < 18 years; ulcer size < 1.5cm in narrowest diameter; ulcer size > 10cm in greatest diameter; wound surrounded by 2cm or less of intact epithelium around the wound edge; wounds that healed following greater than 14 days of traditional treatments
Schwien, 2005^7^ | Retrospective analysis of a database United States | Data from Outcome Concept Systems (OCS) OASIS data warehouse | Industry | Start year 2003; End year 2004 Followup: NR | 2348 | Pressure ulcers or pressure sores | Clinical infection; patients who died at home, enteral or parenteral nutrition therapy, high risk factor of heavy smoking, alcohol dependency, or drug dependency, poor or unknown overall prognosis, secondary diagnoses of uncontrolled DM, cancer, systemic infections, or related to malnutrition/anemias/proteinemia
Yao, 2012^8^ | Cohort United States | NR | NR | Start year: 2002 End year: 2010 Followup: 8 years | 342 | Arterial ulcers; diabetic foot ulcers; pressure ulcers or pressure sores; venous ulcers | Age < 18 years; HIV positive; sickle cell disease; traumatic and burns ulcers; active malignancy with chemotherapy

DM=diabetes mellitus; HIV=Human Immunodeficiency Virus; N=number; NA=not available/not applicable; NPWT=negative pressure wound therapy; NR= not reported; RCT= randomized controlled trial

Table 2 Study Population Characteristics of Included Studies

Author, Year | Arm | Arm Description | N Enrolled | Mean Age (years) | Males, N (%) | Smoker, N (%) | Wound Etiology, % | Wound Location, % | Mean Wound Age (weeks) | Mean Wound Size (cm^2^) | Infection Status,%
Armstrong 2011^1^ | SNaP | Smart Negative Pressure (SNaP®) Wound Care System | 32 | 65.8 | 15^*^ (48) | 6^*^ (20) | NR | NR | NR | NR | NR
Armstrong 2011^1^ | VAC | NA | 33 | 65.1 | 16^*^(50) | 4^*^(12.5) | NR | NR | NR | NR | NR
Armstrong 2011^1^ | Total | Total | 65 | NR | 31^*^(48.5^*^) | 10^*^(15.4^*^) | NR | NR | NR | NR | NR
Armstrong 2012^2^ | SNaP | Smart Negative Pressure (SNaP®) Wound Care System | 64 | 65.0 | 31^*^(48.4) | 11^*^(17.2) | NR | NR | 52.4 | 5.37 | NR
Armstrong 2012^2^ | VAC | NA | 68 | 65.6 | 43^*^(63.2) | 5^*^(7.4) | NR | NR | 68.8 | 9.95 | NR
Armstrong 2012^2^ | Total | Total | 132 | R | 74^*^(56.1^*^) | 16^*^(12^*^) | NR | NR | NR | NR | NR
Fife, 2008^3^ | NPWT | Period of time when receiving NPWT therapy | 72 | NR | NR | NR | Diabetic: 100 | NR | NR | NR | NR
Fife, 2008^3^ | Control | Non NPWT. Patients who did not receive NPWT or prior to receiving NPWT | 1299 | NR | NR | NR | Diabetic: 100 | NR | NR | NR | NR
Fife, 2008^3^ | Total | Total | 1331 | Mean: 60.4 Min: 1 Max: 104 | NR | 142^*^(10.7) Smoking defined as tobacco abuse | Diabetic: 100 | NR | NR | NR | NR
Ford, 2002^4^ | NPWT | VAC | NR | 41.7 | NR | NR | NR | NR | NR | NR | NR
Ford, 2002^4^ | Control | Healthpoint System HP | NR | 54.4 | NR | NR | NR | NR | NR | NR | NR
Ford, 2002^4^ | Total | Total | 28 N of ulcers present: 41 N of ulcers being treated: NR | NR | NR | NR | Pressure: 100 | Leg; 2.9^*^ Foot: 11.4^*^ Ankle: 11.4^*^ Sacral: 48.6^*^ Coccyx: 0 Other: 25.7 | NR | NR | NR
Lavery, 2007^5^ | NPWT | Obtained through KCI database | 2091 | 65.2 | 1349^*^(64.5) | NR | Diabetic: 100 | NR | 22.9 | 13.5 | NR
Lavery, 2007^5^ | NPWT-Matched | Excluded patients older than 70 years and those with wounds of less than 1 month in duration | 1135 | 58.5 | 732^*^(64.5) | NR | Diabetic: 100 | NR | 26.5 | 13.8 | NR
Lavery, 2007^5^ | Control | Margolis pooled analysis | 586 | 58.0 | NR (73.2) | NR | Diabetic: 100 | NR | 30 | 1.61 | NR
Lavery, 2007^5^ | Total | Total | NR | NR | NR | NR | Diabetic: 100 | NR | NR | NR | NR
Lerman, 2010^6^ | NPWT | SNaP | 36 | 64.0 | 9 (42.9) | 9 (42.9) | Diabetic: 47.6 Venous: 52.4 | NR | 36.4 | NR | NR
Lerman, 2010^6^ | Control | Match | 42 | 66.8 | 19 (45.2) | 8 (20.0) | Diabetic: 50 Venous: 50 | NR | 31.2 | NR | NR
Lerman, 2010^6^ | Total | Total | NR | NR | 28 (44.4) | 17 (27.9) | Diabetic: 49.2 Venous: 50.8 | NR | NR | NR | NR
Schwien, 2005^7^ | NPWT | NA | 60 | Mean: 65.0 Min range: 21 Max range: 90 | 28^*^ (47^*^) | NR | Pressure: 100 | NR | NR | NR | NR
Schwien, 2005^7^ | Control | NA | 2288 | Mean: 71.4 Min range: 18 Max range: 106 | 961^*^ (42^*^) | NR | Pressure: 100 | NR | NR | NR | NR
Schwien, 2005^7^ | Total | Total | 2348^*^ | NR | 989^*^ (42.1^*^) | NR | Pressure: 100^*^ | NR | NR | NR | NR
Yao, 2012^8^ | NPWT | | 171 | 60.8 | 99 (57.9) | 67 (40.6) | Diabetic: 81.8 Pressure: 13.45 Venous: 8.8 Arterial: 66.7 | Leg: 15.7 Foot: 84.21^*^ | NR | NR | 79.5
Yao, 2012^8^ | Control | Non NPWT | 171 | 61.3 | 99 (57.9) | 59 (34.5) | Diabetic: 69.4 Pressure: 10.1 Venous: 10.6 Arterial: 34.9 | Leg: 29.2 Foot: 70.76^*^ | NR | NR | 91.1
Yao, 2012^8^ | Total | Total | 342 | NR | 198^*^ (57.9^*^) | NR | NR | Leg: 22.51^*^ Foot: 77.48^*^ | NR | NR | 84.8^*^

ABI=ankle brachial index; *=calculated; Diabetic= diabetic foot ulcer; Max=maximum range; Min= minimum range; N=number; NPWT=negative pressure wound therapy; NR=not reported; Pressure=pressure ulcer; TBI=toe brachial index; VAC=vacuum assisted closure; Venous=venous stasis ulcer

None of the studies reported on vascular status or glycemic control.

Table 3 Study Intervention Details of Included Studies

Author, Year | Arm Details | NPWT brand Model Portable | Dressing Type Recommended Changing Interval | Suction Pressure Setting (mmHg) | Reusable | Instillation System | Duration of Use (weeks) | Prior to NPWT
Armstrong, 2011^1^ | SNaP | Spiracur SNaP® NR | Gauze Every 3 days | NR NR | NR | NR | NR | Debridement
Armstrong, 2011^1^ | VAC | KCI ActiV.A.C.® and V.A.C. Freedom® Portable | Foam Every 2 days | NR NR | NR | NR | NR | Debridement
Armstrong, 2012^2^ | SNaP | Spiracur SNaP® Portable | NR NR | Continuous NR | Single use | NR | NR | Debridement
Armstrong, 2012^2^ | VAC | KCI ActiV.A.C.® system and V.A.C. Freedom™ Portable | NR NR | NR NR | NR | NR | NR | Debridement
Fife, 2008^3^ | Control Unspecified wound care treatment either prior to the start of NPWT or among patients who never received NPWT | NA | NA | NA | NA | NA | NA | NA
Fife, 2008^3^ | NPWT | KCI V.A.C® Therapy NR | NR NR | NR NR | NR | NR | NR | NR
Ford, 2002^4^ | Control The Healthpoint System HP consists of 3 FDA-approved gel products Accuzyme, Iodosorb, and Panafil each targeted to optimize a particular macroscopic phase of wound healing. | NA | NA | NA | NA | NA | NA | NA
Ford, 2002^4^ | NPWT | NR NR NR | NR Every 2 days | NR NR | NR | NR | 6 | Debridement
Lavery, 2007^5^ | Control Standard wet-to-moist wound therapy | NA | NA | NA | NA | NA | NA | NA
Lavery, 2007^5^ | NPWT | KCI V.A.C.® Therapy NR | NR NR | NR NR | NR | NR | NR | NR
Lavery, 2007^5^ | NPWT-Matched | KCI V.A.C® Therapy NR | NR NR | NR NR | NR | NR | NR | NR
Lerman, 2010^6^ | Control Modern wound care protocols that included the use of Apligraf, Regranex, and skin grafting. | NA | NA | NA | NA | NA | NA | NA
Lerman, 2010^6^ | NPWT | SNaP® NR Portable | Gauze: antimicrobial Other: hydrocolloid dressing layer Twice weekly | Multiple setting 75–125 | Single use | NR | 7.44 | Debridement
Schwien, 2005^7^ | Control Any other wound care therapy other than NPWT | NA | NA | NA | NA | NA | NA | NA
Schwien, 2005^7^ | NPWT | KCI NR | Foam: Open cell Every 2 days | Intermittent; Continuous NR | NR | NR | NR | NR
Yao, 2012^8^ | Control NR | NA | NA | NA | NA | NA | NA | NA
Yao, 2012^8^ | NPWT | KCI NR NR | NR NR | NR NR | NR | NR | ≥1 | NR

FDA=U.S. Food and Drug Administration; KCI= Kinetic Concepts, Inc; NA=not available/not applicable; NPWT=negative pressure wound therapy; NR=not reported

Table 4 Clinical Outcome: Complete wound healing by secondary intention- Arterial Ulcers

Author, Year | Arm | N Enrolled | N Analyzed | N of Events | Person- Years | Event Rate per 100 Person- Years | Within Arm Comparison | Between Arm Comparison
Yao, 2012^8^ | Control | NR | 59 | 37 | 102.89 | 35.96 (95% CI, 26.05 to 49.63) | NR
Yao, 2012^8^ | NPWT | NR | 114 | 78 | 99.54 | 78.36 (95% CI, 62.56 to 97.83) | NR | Unadj HR: 2.33 (95% CI, 1.57 to 3.48) adj HR: 2.27 (95% CI, 1.56 to 3.78) Ref group: control Adj for: DM, peripheral arterial disease, coronary heart disease, CKD, CHF, stroke, smoking etc

adj=adjusted; CHF= congestive heart failure; CI = conflidence interval; CKD=chronic kidney disease; DM=diabetes mellitus; HCL=higher confidence limit; HR=hazard ratio; N=number; unadj=unadjusted

Table 5a Clinical Outcome: Complete wound healing by secondary intention-Diabetic Foot Ulcers

Author, Year | Arm | Subgroup | Outcome Description | Timepoint | N Enrolled | N Analyzed | Events | Person- Years | Event Rate per 100 Person- Years | Between Arm Comparison
Lavery, 2007^5^ | Control | All participants | Wound healing was defined as wound completely healed | 12 weeks | 586 | NR | 23.9% | NR | NR | NR
Lavery, 2007^5^ | Control | Small ulcers <2 cm^2^ | | 12 weeks | 347 | NR | 29.4% | NR | NR | NR
Lavery, 2007^5^ | Control | Medium ulcers 2–4 cm^2^ | | 12 weeks | 123 | NR | 17.9% | NR | NR | NR
Lavery, 2007^5^ | Control | Large ulcers >4 cm^2^ | | 12 weeks | 116 | NR | 13.8% | NR | NR | NR
Lavery, 2007^5^ | Control | Short duration <6 months | | 12 weeks | 202 | NR | 30.2% | NR | NR | NR
Lavery, 2007^5^ | Control | Medium duration 6–12 months | | 12 weeks | 88 | NR | 28.4% | NR | NR | NR
Lavery, 2007^5^ | Control | Long duration >12 months | | 12 weeks | 189 | NR | 15.3% | NR | NR | NR
Lavery, 2007^5^ | NPWT-Matched | All participants | Wound closure through secondary intention or through surgical intervention of if adequate granulation for closure by these methods were documented | 12 weeks | 1135 | NR | 39.5% | NR | NR | NR
Lavery, 2007^5^ | NPWT-Matched | Small ulcers <2 cm^2^ | | 12 weeks | 181 | NR | 43.1% | NR | NR | NR
Lavery, 2007^5^ | NPWT-Matched | Medium ulcers 2–4 cm^2^ | | 12 weeks | 167 | NR | 43.7% | NR | NR | NR
Lavery, 2007^5^ | NPWT-Matched | Large ulcers >4 cm^2^ | | 12 weeks | 787 | NR | 37.8% | NR | NR | NR
Lavery, 2007^5^ | NPWT-Matched | Short duration <6 months | | 12 weeks | 787 | NR | 40.3% | NR | NR | NR
Lavery, 2007^5^ | NPWT-Matched | Medium duration 6–12 months | | 12 weeks | 169 | NR | 39.6% | NR | NR | NR
Lavery, 2007^5^ | NPWT-Matched | Long duration >12 months | | 12 weeks | 179 | NR | 35.8% | NR | NR | NR
Lavery, 2007^5^ | NPWT | Small ulcers <2 cm^2^ | Wound closure through secondary intention or through surgical intervention of if adequate granulation for closure by these methods were documented | 12 weeks | 343 | NR | 41.4% | NR | NR | NR
Lavery, 2007^5^ | NPWT | Medium ulcers 2–4 cm^2^ | | 12 weeks | 323 | NR | 40.1% | NR | NR | NR
Lavery, 2007^5^ | NPWT | Large ulcers >4 cm^2^ | | 12 weeks | 1425 | NR | 37.8% | NR | NR | NR
Lavery, 2007^5^ | NPWT | Short duration <6 months | | 12 weeks | 1543 | NR | 39.9% | NR | NR | NR
Lavery, 2007^5^ | NPWT | Medium duration 6–12 months | | 12 weeks | 279 | NR | 36.2% | NR | NR | NR
Lavery, 2007^5^ | NPWT | Long duration >12 months | | 12 weeks | 269 | NR | 35.3% | NR | NR | NR
Yao, 2012^8^ | Control | Diabetic ulcer | Healed wounds | NR | NR | 118 | N: 80 | 205.65 | 38.9 (95% CI, 31.25 to 48.43)
Yao, 2012^8^ | NPWT | Diabetic ulcer | Healed wounds | NR | NR | 140 | N: 94 | 112.01 | 83.92 (95% CI, 68.56 to 102.72) | Unadj HR: 2.33 (95% CI, 1.57 to 3.48) adj HR: 2.27 (95% CI, 1.56 to 3.78) Ref group: control Adj for: DM, peripheral arterial disease, coronary heart disease, CKD, CHF, stroke, smoking etc

adj=adjusted; CHF = congestive heart failure; CI = confidence interval; CKD = chronic kidney disease; DM = diabetes mellitus; N=number; NPWT=negative pressure wound therapy; NR= not reported; unadj=unadjusted

Table 5b Adverse Event: Bleeding-Diabetic Foot Ulcers

Author, Year | Arm | Subgroup | Outcome Description | Timepoint | N Enrolled | N Analyzed | Events | Within Arm Comparison | Between Arm Comparison
Fife, 2008^3^ | Control | All Participants | Discontinued NPWT due to bleeding | NR | 1299 | NR | Count: NR | NR | NR
Fife, 2008^3^ | NPWT | All Participants | Discontinued NPWT due to bleeding | NR | 72 | NR | Count: 0 | NR | NR
Fife, 2008^3^ | Control | All Participants | Sanguineous drainage | NR | 1299 | NR | Count: 0 | NR | NR
Fife, 2008^3^ | NPWT | All Participants | Sanguineous drainage | NR | 72 | NR | Count: 0 | NR | NR

N=number; NPWT=negative pressure wound therapy; NR=not reported

Table 5c Adverse Event: Infection-Diabetic Foot Ulcers

Author, Year | Arm | Subgroup | Outcome Description | Timepoint | N Enrolled | N Analyzed | Events | Within Arm Comparison | Between Arm Comparison
Fife, 2008^3^ | Control | All Participants | N of antibiotic prescriptions | NR | 1299 | NR | NR | NR | Reference
Fife, 2008^3^ | NPWT | All Participants | N of antibiotic prescriptions | NR | 72 | NR | NR | NR | P < 0.05 NPWT vs. Control
Fife, 2008^3^ | Control | All Participants | N of cultures | NR | 1299 | NR | NR | NR | Reference
Fife, 2008^3^ | NPWT | All Participants | N of cultures | NR | 72 | NR | NR | NR | P < 0.05 NPWT vs. Control

N=number; NPWT=negative pressure wound therapy; NR=not reported; vs.=versus

Table 5d Adverse Event: Pain-Diabetic Foot Ulcers

Author, Year | Arm | Subgroup | Outcome Description | Timepoint | N Enrolled | N Analyzed | Events | Within Arm Comparison | Between Arm comparison
Fife, 2008^3^ | Control | All Participants | Provision of pain medications | NR | 1299 | NR | NR | NR | Reference
Fife, 2008^3^ | NPWT | All Participants | Provision of pain medications | NR | 72 | NR | NR | NR | P > 0.05 NPWT vs. Control

n=number; NPWT=negative pressure wound therapy; NR=not reported

Table 6a Clinical Outcome: Complete wound healing by secondary intention- Pressure Ulcers

Author, Year | Arm | Subgroup | Outcome Description | Timepoint | N Enrolled | N Analyzed | Events | Person- Years | Event Rate per 100 Person- Years | Between Arm Comparison
Ford, 2002^4^ | Control | All participants | Ulcer healed completely | During the treatment period | NR | 15 | Count: 2 %: 13 | NR | NR | NR
Ford, 2002^4^ | NPWT | All participants | Ulcer healed completely | During the treatment period | NR | 20 | Count: 2 %: 10 | NR | NR | NR
Yao, 2012^8^ | Control | Pressure ulcer | Healed wounds | NR | NR | 17 | N: 13 | 16.77 | 77.52 (95% CI, 45.01 to 133.51) | Reference
Yao, 2012^8^ | NPWT | Pressure ulcer | Healed wounds | NR | NR | 23 | N: 17 | 11.96 | 142.14 (95% CI, 88.36 to 228.65) | Unadj HR: 2.19 (95% CI, 1.03 to 4.66) adj HR: 1.72 (95% CI, 0.43 to 6.95) NPWT vs. Control adj for: DM, peripheral arterial disease, coronary heart disease, CKD, CHF, stroke, smoking etc

adj=adjusted; CHF=congestive heart failure; CKD=chronic kidney disease; DM=diabetes mellitus; HCL=higher confidence limit; HR=hazard ratio; LCL=lower confidence limit; N=number; NPWT=negative pressure wound therapy; NR=not reported; unadj=unadjusted; vs.=versus

Table 6b Adverse Event: Emergency room visits-Pressure Ulcers

Author, Year | Arm | Subgroup | Outcome Description | Timepoint | N Enrolled | N Analyzed | Events | Within Arm Comparison | Between Arm Comparison
Schwien, 2005^7^ | Control | All participants | Instances of emergent care for wound problem | NR | NR | 2288 | N: 189 %: 8 | NR
Schwien, 2005^7^ | NPWT | All participants | Instances of emergent care for wound problem | NR | NR | 60 | N: 0 %: 0 | NR | P < 0.01 NPWT vs. Control
Schwien, 2005^7^ | Control | Stage III pressure ulcers | Instances of emergent care for wound problem | NR | NR | NR | N: 126 %: 7 | NR
Schwien, 2005^7^ | NPWT | Stage III pressure ulcers | Instances of emergent care for wound problem | NR | NR | NR | N: 0 %: 0 | NR | P < 0.01 NPWT vs. Control
Schwien, 2005^7^ | Control | Stage IV pressure ulcers | Instances of emergent care for wound problem | NR | NR | NR | N: 63 %: 11 | NR
Schwien, 2005^7^ | NPWT | Stage IV pressure ulcers | Instances of emergent care for wound problem | NR | NR | NR | N: 0 %: 0 | NR | P < 0.01 NPWT vs. Control

N=number; NPWT=negative pressure wound therapy; NR=not reported; vs.=versus

Table 6c Adverse Event: Extremity Amputation- Pressure Ulcers

Author, Year | Arm | Subgroup | Outcome Description | Timepoint | N Enrolled | N Analyzed | Events | Within Arm Comparison | Between Arm Comparison
Ford, 2002^4^ | Control | All participants | Extremity amputation | NR | NR | NR | N: 0 | NR | NR
Ford, 2002^4^ | NPWT | All participants | Extremity amputation | NR | NR | NR | N: 1 | NR | NR

N=number; NPWT=negative pressure wound therapy; NR=not reported

Table 6d Adverse Event: Infections- Pressure Ulcers

Author, Year | Arm | Subgroup | Outcome Description | Timepoint | N Enrolled | N Analyzed | Events | Within Arm Comparison | Between Arm Comparison
Ford, 2002^4^ | Control | All participants | Sepsis | NR | NR | NR | N: 0 | NR | NR
Ford, 2002^4^ | NPWT | All participants | Sepsis | NR | NR | NR | N: 1 | NR | NR

N=number; NPWT=negative pressure wound therapy; NR=not reported

Table 6e Adverse Event: Unplanned Hospitalizations- Pressure Ulcers

Author, Year | Arm | Subgroup | Outcome Description | Timepoint | N Enrolled | N Analyzed | Events | Within Arm Comparison | Between Arm Comparison
Schwien, 2005^7^ | Control | All participants | Instances of hospitalization for wound problem | NR | NR | 2288 | N: 310 %: 14 | NR
Schwien, 2005^7^ | NPWT | All participants | Instances of hospitalization for wound problem | NR | NR | 60 | N: 3 %: 5 | NR | P < 0.05 NPWT vs. Control
Schwien, 2005^7^ | Control | Stage III pressure ulcers | Instances of hospitalization for wound problem | NR | NR | NR | N: 194 %: 11 | NR
Schwien, 2005^7^ | NPWT | Stage III pressure ulcers | Instances of hospitalization for wound problem | NR | NR | NR | N: 1 %: 3 | NR | P < 0.05 NPWT vs. Control
Schwien, 2005^7^ | Control | Stage IV pressure ulcers | Instances of hospitalization for wound problem | NR | NR | NR | N: 116 %: 20 | NR
Schwien, 2005^7^ | NPWT | Stage IV pressure ulcers | Instances of hospitalization for wound problem | NR | NR | NR | N: 2 %: 7 | NR | P < 0.01 NPWT vs. Control

N=number; NPWT=negative pressure wound therapy; NR=not reported; vs.=versus

Table 7a Clinical Outcome: Complete wound healing by secondary intention- Venous Stasis Ulcers

Author, Year | Arm | Subgroup | Timepoint | N Enrolled | N Analyzed | Events | Person - Years | Event Rate per 100 Person-Years | Between Arm Comparison
Yao, 2012^8^ | Control | Venous ulcers | NR | NR | 18 | N: 14 | 30.69 | 45.62 (95% CI, 27.02 to 77.03) | Reference
Yao, 2012^8^ | NPWT | Venous ulcers | NR | NR | 15 | N: 12 | 7.79 | 154.04 (95% CI, 87.48 to 271.24) | Unadj HR: 4.90 (95% CI, 1.72 to 13.59) adj HR: 6.31 (95% CI, 1.49 to 26.6) NPWT vs. Control adj for: DM, peripheral arterial disease, coronary heart disease, CKD, CHF, stroke, smoking etc

adj=adjusted; CHF=congestive heart failure; CKD=chronic kidney disease; DM=diabetes mellitus; HCL=higher confidence limit; HR=hazard ratio; LCL=lower confidence limit; N=number; NPWT=negative pressure wound therapy; NR=not reported; unadj=unadjusted; vs.=versus

Table 8a Clinical Outcome: Complete wound healing by secondary intention-Mixed population

Author, Year | Arm | Subgroup | Timepoint | N Enrolled | N Analyzed | Person- Years | Events | Event Rate per 100 Person-Years | Between Arm Comparison
Lerman, 2010^6^ | Control | All Participants | 1 month | NR | 42 | NR | KM %: 0 | NR
Lerman, 2010^6^ | NPWT | All Participants | 1 month | NR | 21 | NR | KM %: 0 | NR | Log-Rank P <0.0001 Wilcoxon P = 0.0001
Lerman, 2010^6^ | Control | All Participants | 2 months | NR | 42 | NR | KM %: 7.1 | NR
Lerman, 2010^6^ | NPWT | All Participants | 2 months | NR | 21 | NR | KM %: 20 | NR | Log-Rank P <0.0001 Wilcoxon P = 0.0001
Lerman, 2010^6^ | Control | All Participants | 3 months | NR | 42 | NR | KM %: 21.4 | NR
Lerman, 2010^6^ | NPWT | All Participants | 3 months | NR | 21 | NR | KM %: 66.2 | NR | Log-Rank P <0.0001 Wilcoxon P = 0.0001
Lerman, 2010^6^ | Control | All Participants | 4 months | NR | 42 | NR | KM %: 35.7 | NR
Lerman, 2010^6^ | NPWT | All Participants | 4 months | NR | 21 | NR | KM %: 83.1 | NR | Log-Rank P <0.0001 Wilcoxon P = 0.0001
Yao, 2012^8^ | Control | All ulcers | NR | 171 | 171 | 274.36 | N: 118 | 43.01 (95% CI, 35.91 to 51.51)
Yao, 2012^8^ | NPWT | All ulcers | NR | 171 | 171 | 131.47 | N: 119 | 90.51 (95% CI, 75.63 to 108.32) | Unadj HR: 2.25 (95% CI, 1.73 to 3.96) adj HR: 2.63 (95% CI, 1.87 to 3.70) NPWT vs. Control adj for: DM, peripheral arterial disease, coronary heart disease, CKD, CHF, stroke, smoking etc
Yao, 2012^8^ | Control | Grade I ulcers superficial ulcer involving skin only | NR | NR | 67 | 77.41 | N: 51 | 65.88 (95% CI, 50.07 to 86.69) | NR
Yao, 2012^8^ | NPWT | Grade I ulcers superficial ulcer involving skin only | NR | NR | 85 | 56.51 | N: 61 | 107.95 (95% CI, 83.99 to 138.74) | NR
Yao, 2012^8^ | Control | Grade II ulcers deep ulcer involving muscle/ tendon/bone | NR | NR | 100 | 194.41 | N: 65 | 33.43 (95% CI, 26.22 to 42.63) | NR
Yao, 2012^8^ | NPWT | Grade II ulcers deep ulcer involving muscle/ tendon/bone | NR | NR | 85 | 74.96 | N: 58 | 77.96 (95% CI, 59.81 to 100.08) | NR

adj=adjusted; CHF=congestive heart failure; CKD=chronic kidney disease; DM=diabetes mellitus; HCL=higher confidence limit; HR=hazard ratio; KM=Kaplan-Meier estimates; LCL=lower confidence limit; N=number; NPWT=negative pressure wound therapy; NR=not reported; unadj=unadjusted; vs.=versus

Table 8b Clinical Outcome: Time to complete wound healing by secondary intention- Mixed population

Author, Year | Arm | Subgroup | Timepoint | N Enrolled | N Analyzed | Person- Years | Events | Between Arm Comparison
Lerman, 2010^6^ | Control | All participants | NR | NR | NA | NR | Average days per KM: 148.73
Lerman, 2010^6^ | NPWT | All participants | NR | NR | 21 | NR | Average days per KM: 74.25 | Log Rank P < 0.0001 NPWT vs. Control

KM= Kaplan-Meier estimates; N=number; NPWT=negative pressure wound therapy; NR=not reported; vs.=versus

Table 8c Adverse Event: Unspecified- Mixed population

Author, Year | Arm | Subgroup | Outcome Description | Timepoint | N Enrolled | N Analyzed | Events | Within Arm Comparison | Between Arm Comparison
Lerman, 2010^6^ | Control | All participants | NR | NR | NA | NR | NR | NR | NR
Lerman, 2010^6^ | NPWT | All participants | NR | NR | 36 | NR | Counts: 7 | NR | NR

N=number; NPWT=negative pressure wound therapy; NR=not reported

Table 8d Adverse Event: Infections- Mixed population

Author, Year | Arm | Subgroup | Outcome Description | Timepoint | N Enrolled | N Analyzed | Events | Within Arm Comparison | Between Arm Comparison
Lerman, 2010^6^ | Control | All participants | Wound infection requiring discontinuation of NPWT | NR | NA | NR | NA | NR | NR
Lerman, 2010^6^ | NPWT | All participants | Wound infection requiring discontinuation of NPWT | NR | 36 | NR | Counts: 1 | NR | NR

N=number; NA=not available; NPWT=negative pressure wound therapy; NR=not reported

Table 9a KQ3 Clinical Outcome: Complete wound healing by secondary intention

Author, Year | Arm | Subgroup | Outcome Description | Timepoint | N Enrolled | Events
Armstrong, 2012^2^ | SNaP | All participants | NR | 0–4 weeks | 64 | 5.3%
Armstrong, 2012^2^ | VAC | All participants | NR | 0–4 weeks | 68 | 9.2%
Armstrong, 2011^1^ | SNaP | All participants | NR | 4 weeks | 32 | 0%
Armstrong, 2011^1^ | VAC | All participants | NR | 4 weeks | 33 | 0%

N=number; NPWT=negative pressure wound therapy; NR=not reported

Table 9b KQ3 Adverse Event: Infection

Author, Year | Arm | Subgroup | Outcome Description | Timepoint | N Enrolled | N Analyzed | Events
Armstrong, 2012^2^ | SNaP | All participants | NR | NR | 64 | 64 | Count: 2 %: 3.1
Armstrong, 2012^2^ | VAC | All participants | NR | NR | 68 | 68 | Count: 5 %: 7.4
Armstrong, 2011^1^ | SNaP | All participants | NR | NR | 32 | 32 | Count: 2 %: 6.3
Armstrong, 2011^1^ | VAC | All participants | NR | NR | 33 | 33 | Count: 1 %: 3.0

N=number; NPWT=negative pressure wound therapy; NR=not repo

Table 9c KQ3 Adverse Event: Pain

Author, Year | Arm | Subgroup | Outcome Description | Timepoint | N Analyzed | Events | Between Arm Comparison
Armstrong, 2012^2^ | SNaP | All participants | Pain | NR | 64 | Count: 1 %: 1.6 | NR
Armstrong, 2012^2^ | VAC | All participants | Pain | NR | 68 | Count: 4 %: 5.9 | NR
Armstrong, 2012^2^ | SNaP | All participants | Pain What was your overall discomfort from using the NPWT device? | Exit survey | 53 | NR
Armstrong, 2012^2^ | VAC | All participants | Pain What was your overall discomfort from using the NPWT device? | Exit survey | 52 | NR | Fisher's Exact Test: 0.0432 VAC vs.SNaP
Armstrong, 2012^2^ | SNaP | High level of discomfort | Pain What was your overall discomfort from using the NPWT device? | Exit survey | 53 | Count: 1 %: 1.9 | NR
Armstrong, 2012^2^ | VAC | High level of discomfort | Pain What was your overall discomfort from using the NPWT device? | Exit survey | 52 | Count: 4 %: 7.7 | NR
Armstrong, 2012^2^ | SNaP | Low level of discomfort | Pain What was your overall discomfort from using the NPWT device? | Exit survey | 53 | Count: 8 %: 15.1 | NR
Armstrong, 2012^2^ | VAC | Low level of discomfort | Pain What was your overall discomfort from using the NPWT device? | Exit survey | 52 | Count: 13 %: 25.0 | NR
Armstrong, 2012^2^ | SNaP | Moderate discomfort | Pain What was your overall discomfort from using the NPWT device? | Exit survey | 53 | Count: 7 %: 13.2 | NR
Armstrong, 2012^2^ | VAC | Moderate discomfort | Pain What was your overall discomfort from using the NPWT device? | Exit survey | 52 | Count: 11 %: 21.2 | NR
Armstrong, 2012^2^ | SNaP | Minimum discomfort | Pain What was your overall discomfort from using the NPWT device? | Exit survey | 53 | Count: 16 %: 30.2 | NR
Armstrong, 2012^2^ | VAC | M inimum discomfort | Pain What was your overall discomfort from using the NPWT device? | Exit survey | 52 | Count: 16 %: 30.8 | NR
Armstrong, 2012^2^ | SNaP | No discomfort | Pain What was your overall discomfort from using the NPWT device? | Exit survey | 53 | Count: 21 %: 39.6 | NR
Armstrong, 2012^2^ | VAC | No discomfort | Pain What was your overall discomfort from using the NPWT device? | Exit survey | 52 | Count: 8 %: 15.4 | NR
Armstrong, 2012^2^ | SNaP | All participants | What was your level of pain associated with dressing changes for the NPWT device? | Exit survey | 53 | Sum of scores: 2545.50 Expected sum of scores: 2809.0 SD of sum: 148.52 | NR
Armstrong, 2012^2^ | VAC | All participants | What was your level of pain associated with dressing changes for the NPWT device? | Exit survey | 52 | Sum of scores: 3019.50 Expected sum of scores: 2756.0 SD of sum: 148.52 | Wilcoxon Test P = 0.0795 VAC vs.SNaP
Armstrong, 2012^2^ | SNaP | All participants | What was your level of pain associated with just wearing the NPWT device? | Exit survey | 53 | Sum of scores: 2659.0 Expected sum of scores: 2809.0 SD of sum: 141.84
Armstrong, 2012^2^ | VAC | All participants | What was your level of pain associated with just wearing the NPWT device? | Exit survey | 52 | Sum of scores: 2906.0 Expected sum of scores: 2756.0 SD of sum: 141.84 | Wilcoxon Test P = 0.2943 VAC vs.SNaP
Armstrong, 2012^2^ | SNaP | All participants | What was your overall level of pain associated with treatment with the NPWT device? | Exit survey | 53 | Sum of scores: 2588.50 Expected sum of scores: 2809.0 SD of sum: 147.49
Armstrong, 2012^2^ | VAC | All participants | What was your overall level of pain associated with treatment with the NPWT device? | Exit survey | 52 | Sum of scores: 2976.50 Expected sum of scores: 2756.0 SD of sum: 147.49 | Wilcoxon Test P = 0.1388 VAC vs.SNaP
Armstrong, 2011^1^ | SNaP | All participants | What was your level of pain associated with just wearing the NPWT device? | Exit survey | 11 | Sum of scores: 102.5 Expected sum of scores: 126.5 SD of sum: 14.434
Armstrong, 2011^1^ | VAC | All participants | What was your level of pain associated with just wearing the NPWT device? | Exit survey | 11 | Sum of scores: 150.5 Expected sum of scores: 126.5 SD of sum: 14.434 | Wilcoxon P = 0.1184 t test P-value: 0.0403 VAC vs.SNaP
Armstrong, 2011^1^ | SNaP | All participants | Pain What was your overall discomfort from using the NPWT device? | Exit survey | 13
Armstrong, 2011^1^ | VAC | All participants | Pain What was your overall discomfort from using the NPWT device? | Exit survey | 12 | | Fisher's Exact Test: 0.0282 Chi-Squared P = 0.0424 VAC vs.SNaP
Armstrong, 2011^1^ | SNaP | High level of discomfort | Pain What was your overall discomfort from using the NPWT device? | Exit survey | 13 | Count: 0 %: 0.0 | NR
Armstrong, 2011^1^ | VAC | High level of discomfort | Pain What was your overall discomfort from using the NPWT device? | Exit survey | 12 | Count: 1 %: 8.3 | NR
Armstrong, 2011^1^ | SNaP | Low level of discomfort | Pain What was your overall discomfort from using the NPWT device? | Exit survey | 13 | Count: 2 %: 15.4 | NR
Armstrong, 2011^1^ | VAC | Low level of discomfort | Pain What was your overall discomfort from using the NPWT device? | Exit survey | 12 | Count: 12 %: 16.7 | NR
Armstrong, 2011^1^ | SNaP | Moderate discomfort | Pain What was your overall discomfort from using the NPWT device? | Exit survey | 13 | Count: 1 %: 7.7 | NR
Armstrong, 2011^1^ | VAC | Moderate discomfort | Pain What was your overall discomfort from using the NPWT device? | Exit survey | 12 | Count: 3 %: 25.0 | NR
Armstrong, 2011^1^ | SNaP | Minimum discomfort | Pain What was your overall discomfort from using the NPWT device? | Exit survey | 13 | Count: 3 %: 23.1 | NR
Armstrong, 2011^1^ | VAC | Minimum discomfort | Pain What was your overall discomfort from using the NPWT device? | Exit survey | 12 | Count: 4 %: 33.3 | NR
Armstrong, 2011^1^ | SNaP | No discomfort | Pain What was your overall discomfort from using the NPWT device? | Exit survey | 13 | Count: 7 %: 53.9 | NR
Armstrong, 2011^1^ | VAC | No discomfort | Pain What was your overall discomfort from using the NPWT device? | Exit survey | 12 | Count: 2 %: 16.7 | NR
Armstrong, 2011^1^ | SNaP | All participants | What was your overall level of pain associated with treatment with the NPWT device? | Exit survey | 12 | Sum of scores: 121.5 Expected sum of scores: 150.0 SD of sum: 16.89
Armstrong, 2011^1^ | VAC | All participants | What was your overall level of pain associated with treatment with the NPWT device? | Exit survey | 12 | Sum of scores: 178.5 Expected sum of scores: 150.0 SD of sum: 16.89 | Wilcoxon P = 0.111 t test P = 0.0696 VAC vs.SNaP
Armstrong, 2011^1^ | SNaP | All participants | What was your level of pain associated with dressing changes for the NPWT device? | Exit survey | 13 | Sum of scores: 112.5 Expected sum of scores: 144.0 SD of sum: 15.664
Armstrong, 2011^1^ | VAC | All participants | What was your level of pain associated with dressing changes for the NPWT device? | Exit survey | 12 | Sum of scores: 163.5 Expected sum of scores: 132.0 SD of sum: 15.664 | Wilcoxon P = 0.0605 t test P = 0.0245 VAC vs.SNaP

N=number; NPWT=negative pressure wound therapy; NR=not reported; SD=standard deviation; vs.=versus

Table 9d KQ3 Patient-centered Outcome: Return to prior level of functional activity

Author, Year | Arm | Subgroup | Outcome Description | Timepoint | N Analyzed | Events | Between Arm Comparison
Armstrong, 2012^2^ | SNaP | All participants | After treatment with the NPWT, how did your overall activity level change? | Exit survey | 53 | Count: NA
Armstrong, 2012^2^ | VAC | All participants | After treatment with the NPWT, how did your overall activity level change? | Exit survey | 52 | Count: NA | Fisher's Exact Test P < 0.05 VAC vs. SNaP
Armstrong, 2012^2^ | SNaP | Less active | After treatment with the NPWT, how did your overall activity level change? | Exit survey | 53 | Count: 9 %: 17.0 | NR
Armstrong, 2012^2^ | VAC | Less active | After treatment with the NPWT, how did your overall activity level change? | Exit survey | 52 | Count: 27 %: 51.9 | NR
Armstrong, 2012^2^ | SNaP | More active | After treatment with the NPWT, how did your overall activity level change? | Exit survey | 53 | Count: 6 %: 11.3 | NR
Armstrong, 2012^2^ | VAC | More active | After treatment with the NPWT, how did your overall activity level change? | Exit survey | 52 | Count: 2 %: 3.9 | NR
Armstrong, 2012^2^ | SNaP | Stayed the same | After treatment with the NPWT, how did your overall activity level change? | Exit survey | 53 | Count: 38 %: 71.7 | NR
Armstrong, 2012^2^ | VAC | Stayed the same | After treatment with the NPWT, how did your overall activity level change? | Exit survey | 52 | Count: 23 %: 44.2 | NR
Armstrong, 2012^2^ | SNaP | Agree | I was able to work and do my normal daily activity while being treated with the NPWT? | Exit survey | 53 | Count: 23 %: 43.4 | NR
Armstrong, 2012^2^ | VAC | Agree | I was able to work and do my normal daily activity while being treated with the NPWT? | Exit survey | 52 | Count: 25 %: 48.1 | NR
Armstrong, 2012^2^ | SNaP | Disagree | I was able to work and do my normal daily activity while being treated with the NPWT? | Exit survey | 53 | Count: 3 %: 5.7 | NR
Armstrong, 2012^2^ | VAC | Disagree | I was able to work and do my normal daily activity while being treated with the NPWT? | Exit survey | 52 | Count: 11 %: 21.2 | NR
Armstrong, 2012^2^ | SNaP | Neutral | I was able to work and do my normal daily activity while being treated with the NPWT? | Exit survey | 53 | Count: 7 %: 13.2 | NR
Armstrong, 2012^2^ | VAC | Neutral | I was able to work and do my normal daily activity while being treated with the NPWT? | Exit survey | 52 | Count: 7 %: 13.5 | NR
Armstrong, 2012^2^ | SNaP | Strongly agree | I was able to work and do my normal daily activity while being treated with the NPWT? | Exit survey | 53 | Count: 19 %: 35.9 | NR
Armstrong, 2012^2^ | VAC | Strongly agree | I was able to work and do my normal daily activity while being treated with the NPWT? | Exit survey | 52 | Count: 5 %: 9.6 | NR
Armstrong, 2012^2^ | SNaP | Strongly disagree | I was able to work and do my normal daily activity while being treated with the NPWT? | Exit survey | 53 | Count: 1 %: 1.9 | NR
Armstrong, 2012^2^ | VAC | Strongly disagree | I was able to work and do my normal daily activity while being treated with the NPWT? | Exit survey | 52 | Count: 4 %: 7.7 | NR
Armstrong, 2011^1^ | SNaP | All participants | After treatment with the NPWT, how did your overall activity level change? | Exit survey | 13 | NR
Armstrong, 2011^1^ | VAC | All participants | After treatment with the NPWT, how did your overall activity level change? | Exit survey | 12 | NR | Chi-square P = 0.0210 Fisher's Exact Test P = 0.0179 VAC vs.SNaP
Armstrong, 2011^1^ | SNaP | Less active | After treatment with the NPWT, how did your overall activity level change? | Exit survey | 13 | Count: 1 %: 7.7 | NR
Armstrong, 2011^1^ | VAC | Less active | After treatment with the NPWT, how did your overall activity level change? | Exit survey | 12 | Count: 7 %: 58.3 | NR
Armstrong, 2011^1^ | SNaP | More active | After treatment with the NPWT, how did your overall activity level change? | Exit survey | 13 | Count: 1 %: 7.7 | NR
Armstrong, 2011^1^ | VAC | More active | After treatment with the NPWT, how did your overall activity level change? | Exit survey | 12 | Count: 0 %: 0 | NR
Armstrong, 2011^1^ | SNaP | Stayed the same | After treatment with the NPWT, how did your overall activity level change? | Exit survey | 13 | Count: 11 %: 84.6 | NR
Armstrong, 2011^1^ | VAC | Stayed the same | After treatment with the NPWT, how did your overall activity level change? | Exit survey | 12 | Count: 5 %: 41.7 | NR
Armstrong, 2011^1^ | SNaP | Overall | After treatment with the NPWT, how did your overall activity level change? | Exit survey | 13 | Count: NR %: NR | NR
Armstrong, 2011^1^ | VAC | Overall | After treatment with the NPWT, how did your overall activity level change? | Exit survey | 12 | Count: NR %: NR | Chi-square P = 0.0210 Fisher's Exact Test P = 0.0179 VAC vs.SNaP
Armstrong, 2011^1^ | SNaP | All participants | I was able to work and do my normal daily activity while being treated with the NPWT? | Exit survey | NR | NR
Armstrong, 2011^1^ | VAC | All participants | I was able to work and do my normal daily activity while being treated with the NPWT? | Exit survey | NR | NR | Chi-square P = 0.0068 Fisher's Exact Test : 0.0038 VAC vs.SNaP
Armstrong, 2011^1^ | SNaP | Agree | I was able to work and do my normal daily activity while being treated with the NPWT? | Exit survey | 13 | Count: 6 %: 46.2 | NR
Armstrong, 2011^1^ | VAC | Agree | I was able to work and do my normal daily activity while being treated with the NPWT? | Exit survey | 12 | Count: 4 %: 33.3 | NR
Armstrong, 2011^1^ | SNaP | Disagree | I was able to work and do my normal daily activity while being treated with the NPWT? | Exit survey | 13 | Count: 0 %: 0 | NR
Armstrong, 2011^1^ | VAC | Disagree | I was able to work and do my normal daily activity while being treated with the NPWT? | Exit survey | 12 | Count: 4 %: 33.3 | NR
Armstrong, 2011^1^ | SNaP | Neutral | I was able to work and do my normal daily activity while being treated with the NPWT? | Exit survey | 13 | Count: 1 %: 7.7 | NR
Armstrong, 2011^1^ | VAC | Neutral | I was able to work and do my normal daily activity while being treated with the NPWT? | Exit survey | 12 | Count: 4 %: 33.3 | NR
Armstrong, 2011^1^ | SNaP | Strongly agree | I was able to work and do my normal daily activity while being treated with the NPWT? | Exit survey | 13 | Count: 6 %: 46.2 | NR
Armstrong, 2011^1^ | VAC | Strongly agree | I was able to work and do my normal daily activity while being treated with the NPWT? | Exit survey | 12 | Count: 0 %: 0 | NR
Armstrong, 2011^1^ | SNaP | Strongly disagree | I was able to work and do my normal daily activity while being treated with the NPWT? | Exit survey | 13 | Count: 0 %: 0 | NR
Armstrong, 2011^1^ | VAC | Strongly disagree | I was able to work and do my normal daily activity while being treated with the NPWT? | Exit survey | 12 | Count: 0 %: 0 | NR

N=number; NA= not applicable/not available; NPWT=negative pressure wound therapy; NR=not reported; SD=standard deviation; vs.=versus

Table 10 Study Quality

Author, Year | What is the risk of selection bias biased allocation to interventions due to inadequate generation of a randomized sequence? | What is the risk of selection bias biased allocation to interventions due to inadequate concealment of allocations before assignment? | For each main outcome or class of outcomes, what is the risk of performance bias due to knowledge of the allocated interventions by participants and personnel during the study lack of study participant and personnel blinding? | For each main outcome or class of outcomes, what is the risk of attrition bias due to amount, nature, or handling of incomplete outcome data? | What is the risk of reporting bias due to selective outcome reporting? | Are there other biases?^*^ | Overall Quality
Armstrong, 2011^1^ | Low | Low | High | High | Low | Unsure | Fair
Armstrong, 2012^2^ | Low | Low | High | High | Low | Unsure | Fair
Fife, 2008^3^ | High | High | High | Low | High | Yes | Poor
Ford, 2002^4^ | Low | Unclear | Medium | Low | High | Yes | Fair
Lavery, 2007^5^ | High | High | High | Unclear | High | Yes | Poor
Lerman, 2010^6^ | High | High | High | High | Unclear | Yes | Poor
Schwien, 2005^7^ | High | High | High | Unclear | Unclear | Yes | Poor
Yao, 2012^8^ | High | High | Low | Low | Unclear | Yes | Fair

* These include the following: documentation of control of underlying disease such as blood sugar measurements in diabetics, and use of compression device in venous stasis ulcers; clear outcome definition

## REFERENCES

1 Armstrong DG, Marston WA, Reyzelman AM, et al. Comparison of negative pressure wound therapy with an ultraportable mechanically powered device vs. traditional electrically powered device for the treatment of chronic lower extremity ulcers: a multicenter randomized-controlled trial. Wound Repair Regen. Mar-Apr. 2011;19(2):173-180. [pmid: 21362084].
2 Armstrong DG, Marston WA, Reyzelman AM, et al. Comparative effectiveness of mechanically and electrically powered negative pressure wound therapy devices: a multicenter randomized controlled trial. Wound Repair Regen. May-Jun. 2012;20(3):332-341. [pmid: 22564228].
3 Fife CE, Walker D, Thomson B, et al. The safety of negative pressure wound therapy using vacuum-assisted closure in diabetic foot ulcers treated in the outpatient setting. Int Wound J. Jun. Suppl 2. 2008;5:17-22. [pmid: 18577134].
4 Ford CN, Reinhard ER, Yeh D, et al. Interim analysis of a prospective, randomized trial of vacuum-assisted closure versus the healthpoint system in the management of pressure ulcers. Ann Plast Surg. Jul. 2002;49(1):55-61. discussion. [pmid: 12142596].
5 Lavery LA, Boulton AJ, Niezgoda JA, et al. A comparison of diabetic foot ulcer outcomes using negative pressure wound therapy versus historical standard of care. Int Wound J. Jun. 2007;4(2):103-113. [pmid: 17651226].
6 Lerman B, Oldenbrook L, Eichstadt SL, et al. Evaluation of chronic wound treatment with the SNaP wound care system versus modern dressing protocols. Plast Reconstr Surg. Oct. 2010;126(4):1253-1261. [pmid: 20885246].
7 Schwien T, Gilbert J, Lang C. Pressure ulcer prevalence and the role of negative pressure wound therapy in home health quality outcomes. Ostomy Wound Manage. Sep. 2005;51(9):47-60. [pmid: 16230764].
8 Yao M, Fabbi M, Hayashi H, et al. A retrospective cohort study evaluating efficacy in high-risk patients with chronic lower extremity ulcers treated with negative pressure wound therapy. Int Wound J. 2012. Nov. 19.