# List of Excluded Studies

1 Ahmed M, Soskova T, Williams DT. Regarding "State-of-the-art treatment of chronic leg ulcers: A randomized controlled trial comparing vacuum-assisted closure (V.A.C.) with modern wound dressings". J Vasc Surg. Sep. 2007;46(3):614-615. author reply 5-6. [pmid: 17826260]. No original data
2 Akbari A, Moodi H, Ghiasi F, et al. Effects of vacuum-compression therapy on healing of diabetic foot ulcers: randomized controlled trial. J Rehabil Res Dev. 2007;44(5):631-636. [pmid: 17943674]. Sample size less than 20 subjects
3 Al-Benna S. Economical negative pressure wound therapy. Ann R Coll Surg Engl. Apr. 2012;94(3):214. [pmid: 22507736]. No original data, Sample size less than 20 subjects
4 Alfano C, Angelisanti M, Calzoni C, et al. Treatment of ulcer and difficult wounds of the lower limbs: our experience. Ann Ital Chir. 2012;83(2):135-141. [pmid: 22462334]. Not conducted in home setting or outpatient setting
5 Armstrong DG, Bluman EM, Gould L, et al. Wound care. Foot Ankle Spec. Jun. 2008;1(3):177-179. [pmid: 19825713]. No original data
6 Armstrong DG, Boulton AJ, Banwell P. Negative pressure wound therapy in treatment of diabetic foot wounds: a marriage of modalities. Ostomy Wound Manage. Apr. 2004;50(4A Suppl):9-12. [pmid: 15317237]. No original data
7 Armstrong DG, Lavery LA, Abu-Rumman P, et al. Outcomes of subatmospheric pressure dressing therapy on wounds of the diabetic foot. Ostomy Wound Manage. Apr. 2002;48(4):64-68. [pmid: 11993062]. Does not have a comparison group
8 Ashby R, Dumville J, Soares MO, et al. A pilot study of negative pressure wound therapy for the treatment of grade III/IV pressure ulcers. The 2011 International Nursing Research Conference. 16–18 May, 2011. Harrogate, UK. 2011:95. Sample size less than 20 subjects
9 Augustin M, Blome C, Zschocke I, et al. Benefit evaluation in the therapy of chronic wounds from the patients' perspective--development and validation of a new method. Wound Repair Regen. Jan-Feb. 2012;20(1):8-14. [pmid: 22150801]. Device not available in the US/not FDA approved, Does not have a comparison group, Does not apply to key questions
10 Augustin M, Zschocke I. Patient evaluation of the benefit of outpatient and inpatient vacuum therapy. Multicenter study with patient-relevant end points. MMW-Fortschritte der Medizin. SUPPL 1. 2006;148:25-32. Not in English and unable to determine eligibility, Does not have a comparison group
11 Ayala J, Payne W, Keith MS. Time to 50% reduction in wound area as a significant predictor of complete wound closure in patients with partial diabetic foot amputations: results from a randomized controlled trial comparing vacuum assisted closure to standard therapy (ST). SAWC 2006. April 30 - May 3, 2006. San Antonio, Texas. 2006. Unable to retrieve article
12 Baharestani MM, Houliston-Otto DB, Barnes S. Early versus late initiation of negative pressure wound therapy: examining the impact on home care length of stay. Ostomy Wound Manage. Nov. 2008;54(11):48-53. [pmid: 19037137]. Does not apply to key questions
13 Baharestani MM. Use of negative pressure wound therapy in the treatment of neonatal and pediatric wounds: a retrospective examination of clinical outcomes. Ostomy Wound Manage. Jun. 2007;53(6):75-85. [pmid: 17586874]. Sample size less than 20 subjects, Does not evaluate patients with chronic wounds, Not conducted in home setting or outpatient setting, Other- pediatric data
14 Bartkowski R, Endrich B. DRG practice: wound management with vacuum therapy. Chirurg. Dec. Suppl. 2007:414-416. [pmid: 18546567]. No original data, Not in English and unable to determine eligibility
15 Beno M, Martin J, Sager P. Vacuum assisted closure in vascular surgery. Bratisl Lek Listy. 2011;112(5):249-52. [pmid: 21682077]. Not conducted in home setting or outpatient setting, Unable to abstract relevant data
16 Beral D, Adair R, Peckham-Cooper A, et al. Chronic wound sepsis due to retained vacuum assisted closure foam. BMJ. 2009;338:b2269. [pmid: 19553260]. Sample size less than 20 subjects, Does not evaluate patients with chronic wounds
17 Blume PA, Sumpio BE. Interim results of a randomized, controlled multicenter trial of vacuum-assisted closure therapy* in the treatment and blinded evaluation of diabetic foot ulcers. 20th Annual Symposium on Advanced Wounds Care and the Wound Healing Society Meeting. 2007, 28 April - 1 May. Tampa, FL. 2007:C126. Meeting abstract, Unable to abstract relevant data
18 Blume PA, Walters J, Payne W, et al. Comparison of negative pressure wound therapy using vacuum-assisted closure with advanced moist wound therapy in the treatment of diabetic foot ulcers: a multicenter randomized controlled trial. Diabetes Care. Apr. 2008;31(4):631-636. [pmid: 18162494]. Not conducted in home setting or outpatient setting
19 Braakenburg A, Obdeijn MC, Feitz R, et al. The clinical efficacy and cost effectiveness of the vacuum-assisted closure technique in the management of acute and chronic wounds: a randomized controlled trial. Plast Reconstr Surg. Aug. 2006;118(2):390-397. discussion 8-400. [pmid: 16874208]. Not conducted in home setting or outpatient setting, Unable to abstract relevant data
20 Brin YS, Mumcuoglu KY, Massarwe S, et al. Chronic foot ulcer management using maggot debridement and topical negative pressure therapy. J Wound Care. Mar. 2007;16(3):111-113. [pmid: 17385586]. Sample size less than 20 subjects, Does not have a comparison group
21 Carson SN, Overall K, Lee-Jahshan S, et al. Vacuum-assisted closure used for healing chronic wounds and skin grafts in the lower extremities. Ostomy Wound Manage. Mar. 2004;50(3):52-58. [pmid: 15206090]. Does not evaluate patients with chronic wounds, Does not have a comparison group
22 Chien SH, Tan WH, Hsu H. New continuous negative-pressure and irrigation treatment for infected wounds and intractable ulcers. Plast Reconstr Surg. Jul. 2008;122(1):318. author reply 9. [pmid: 18594433]. No original data
23 Chiummariello S, Guarro G, Pica A, et al. Evaluation of negative pressure vacuum-assisted system in acute and chronic wounds closure: our experience. G Chir. Oct. 2012;33(10):358-362. [pmid: 23095568]. Device not available in the US/not FDA approved, Does not have a comparison group, Unable to abstract relevant data
24 Clare MP, Fitzgibbons TC, McMullen ST, et al. Experience with the vacuum assisted closure negative pressure technique in the treatment of non-healing diabetic and dysvascular wounds. Foot Ankle Int. Oct. 2002;23(10):896-901. [pmid: 12398140]. Sample size less than 20 subjects, Does not have a comparison group
25 Cooper SM, Young E. Topical negative pressure in the treatment of pressure ulcers. J Am Acad Dermatol. Aug. 1999;41(2 Pt 1):280. [pmid: 10426905]. No original data
26 Crew J, Varilla R, Rocas TA, et al. NeutroPhase((R)) in chronic non-healing wounds. Int J Burns Trauma. 2012;2(3):126-134. [pmid: 23272294]. Sample size less than 20 subjects, No human subjects, Meeting abstract, Does not have a comparison group
27 Crew J, Varilla R, Rocas TA, et al. Conquering chronic nonhealing wounds with pure hypochlorous acid. Wound Repair and Regeneration. 2012;20(2):A19. Meeting abstract
28 Culliford ATt, Spector JA, Levine JP. A novel technique for vacuum assisted closure device application in noncontiguous wounds. J Plast Reconstr Aesthet Surg. 2007;60(1):99-100. [pmid: 17126274]. Sample size less than 20 subjects
29 de Laat EH, van den Boogaard MH, Spauwen PH, et al. Faster wound healing with topical negative pressure therapy in difficult-to-heal wounds: a prospective randomized controlled trial. Ann Plast Surg. Dec. 2011;67(6):626-631. [pmid: 21629111]. Sample size less than 20 subjects, Not conducted in home setting or outpatient setting
30 de Leon J. Negative pressure wound therapy in pressure ulcer management. Ostomy Wound Manage. Feb. 2005;51(2A Suppl):3S-8S. [pmid: 15699557]. Sample size less than 20 subjects, Does not have a comparison group
31 Deaths, injuries associated with Negative Pressure Wound Therapy. Hospital Home Health. 2010;27(3):25-27. No original data
32 Din V, Miteva M, Romanelli P, et al. Immunohistochemical Evaluation of Venous Leg Ulcers Before and After Negative Pressure Wound Therapy. Wounds: A Compendium of Clinical Research & Practice. 2011;23(9):257-266. Does not apply to key questions
33 Dissemond J. Vacuum-therapy of chronic wounds in dermatologic departments. Hautarzt. Aug. 2008;59(8):642-648. [pmid: 18626613]. No original data
34 Djedovic G, Engelhardt TO, Rieger UM, et al. The sandwich technique for vacuum-assisted wound dressing application in the urogenital region: a safe, time-sparing and reliable method. Singapore Med J. Apr. 2012;53(4):294-295. author reply 5. [pmid: 22511061]. No original data, Sample size less than 20 subjects, Does not evaluate patients with chronic wounds
35 Doughty D. WOC nurse wound consult: negative pressure wound therapy. J Wound Ostomy Continence Nurs. Sep-Oct. 2009;36(5):483-485. [pmid: 19752656]. No original data
36 Dowsett C, Davis L, Henderson V, et al. The economic benefits of negative pressure wound therapy in community-based wound care in the NHS. Int Wound J. Oct. 2012;9(5):544-552. [pmid: 22321132]. Does not have a comparison group, Does not apply to key questions
37 Dunbar A, Bowers DM, Holderness H Jr. Silicone net dressing as an adjunct with negative pressure wound therapy. Ostomy Wound Manage. Nov. 2005;51(11A Suppl):21-22. [pmid: 16615743]. Sample size less than 20 subjects, Does not have a comparison group
38 Dunn R, Hurd T, Chadwick P, et al. Factors associated with positive outcomes in 131 patients treated with gauze-based negative pressure wound therapy. Int J Surg. 2011;9(3):258-262. [pmid: 21187174]. Does not have a comparison group
39 Dunn RM, Ignotz R, Mole T, et al. Assessment of gauze-based negative pressure wound therapy in the split-thickness skin graft clinical pathway-an observational study. Eplasty. 2011;11:e14. [pmid: 21436890]. Sample size less than 20 subjects, Does not have a comparison group
40 Durai R, Mownah A, Ng PC. Bridge vacuum-assisted closure: a novel technique of using a single vacuum machine for multiple adjacent wounds. Int J Clin Pract. Jan. 2010;64(1):93-94. [pmid: 20089017]. Sample size less than 20 subjects, Does not evaluate patients with chronic wounds, Not conducted in home setting or outpatient setting
41 Eginton MT, Brown KR, Seabrook GR, et al. A prospective randomized evaluation of negative-pressure wound dressings for diabetic foot wounds. Ann Vasc Surg. Nov. 2003;17(6):645-649. [pmid: 14534844]. Sample size less than 20 subjects
42 Etöz A, Özgenel Y, Özcan M. The use of negative pressure wound therapy on diabetic foot ulcers: a preliminary controlled trial. Wounds: A Compendium of Clinical Research & Practice. 2004;16(8):264-269. Device not available in the US/not FDA approved, Not conducted in home setting or outpatient setting
43 Farah R, Gantus M, Kogan L. Vacuum-assisted therapy for various wound types including diabetic foot ulcer. Harefuah. Mar. 2011;150(3):222-226. 306, 5. [pmid: 21574351]. Not in English and unable to determine eligibility
44 Fluieraru S, Bekara F, Naud M, et al. Sterile-water negative pressure instillation therapy for complex wounds and NPWT failures. J Wound Care. Jun. 2013;22(6):293-294. 6, 8-9. [pmid: 24049811]. Does not have a comparison group
45 Fraccalvieri M, Ruka E, Bocchiotti MA, et al. Patient's pain feedback using negative pressure wound therapy with foam and gauze. Int Wound J. Oct. 2011;8(5):492-499. [pmid: 21827628]. Does not evaluate patients with chronic wounds
46 Fraccalvieri M, Zingarelli E, Ruka E, et al. Negative pressure wound therapy using gauze and foam: histological, immunohistochemical and ultrasonography morphological analysis of the granulation tissue and scar tissue. Preliminary report of a clinical study. Int Wound J. Aug. 2011;8(4):355-364. [pmid: 21564551]. Sample size less than 20 subjects, Does not evaluate patients with chronic wounds
47 Frykberg RG, Williams DV. Negative-pressure wound therapy and diabetic foot amputations: a retrospective study of payer claims data. J Am Podiatr Med Assoc. Sep-Oct. 2007;97(5):351-359. [pmid: 17901338]. Not conducted in home setting or outpatient setting
48 Gesslein M. Therapy of ulcus cruris venosum. Not hiding chronic wounds with bandages but using vacuum sealing. MMW Fortschr Med. Jan. 12. 2006;148(1–2):13. [pmid: 16610404]. No original data, Not in English and unable to determine eligibility
49 Gillespie BM, Finigan T, Kerr D, et al. End-users' assessment of prophylactic negative pressure wound therapy products. Wound Practice & Research. 2013;21(2):74-81. Does not evaluate patients with chronic wounds, Not conducted in home setting or outpatient setting, Does not apply to key questions
50 Giovinco NA, Bui TD, Fisher T, et al. Wound chemotherapy by the use of negative pressure wound therapy and infusion. Eplasty. 2010;10:e9. [pmid: 20090841]. Sample size less than 20 subjects
51 Gnanaraj J, Gnanaraj D, Prasad A. Salvaging a diabetic foot: a new cost-effective method. Trop Doct. Apr. 2012;42(2):88-89. [pmid: 22431826]. Sample size less than 20 subjects, Device not available in the US/not FDA approved
52 Halter G, Kapfer X, Liewald F, et al. Vacuum-sealed mesh graft transplantation in chronic cutaneous ulcers of the lower leg. Vasa. Aug. 2003;32(3):155-158. [pmid: 14524036]. Not conducted in home setting or outpatient setting
53 Halter G, Orend KH, Liewald F, et al. Vacuum sealing in the treatment of ulcus cruris. Phlebologie. 2004;33(4):120-124. Does not have a comparison group
54 Henry SL. A curious side effect of negative pressure wound therapy. Plast Reconstr Surg. Jun. 2006;117(7):2534-2535. [pmid: 16772996]. No original data, Sample size less than 20 subjects, Does not apply to key questions
55 Herzig R, Florek HJ. Finding-adapted surgical treatment of refractory ulcus cruris venosum. Phlebologie. 2002;31(3):69-72. Not in English and unable to determine eligibility, Not conducted in home setting or outpatient setting
56 Hu KX, Zhang HW, Zhou F, et al. Observation on the therapeutic effects of negative-pressure wound therapy on the treatment of complicated and refractory wounds. Zhonghua Shao Shang Za Zhi. Aug. 2009;25(4):249-252. [pmid: 19951540]. Not in English and unable to determine eligibility, Not conducted in home setting or outpatient setting
57 Ino K, Kiyokawa K, Akaiwa K, et al. A team approach to the management of intractable leg ulcers. Ann Vasc Dis. 2013;6(1):39-45. [pmid: 23641282]. Device not available in the US/not FDA approved, Unable to abstract relevant data
58 Janis JE, Attinger CE. The clinical efficacy and cost effectiveness of the vacuum-assisted closure technique in the management of acute and chronic wounds: A randomized controlled trial. Plast Reconstr Surg. 2006;118(2):398-400. No original data
59 Jones SM, Banwell PE, Shakespeare PG, et al. Complications of topical negative pressure therapy in small-diameter wounds. Plast Reconstr Surg. Sep. 1. 2004;114(3):815-817. [pmid: 15318073]. No original data
60 Joseph E, Hamori CA, Bergman S, et al. New therapeutic approaches in wound care. A prospective randomized trial of vacuum-assisted closure versus standard therapy of chronic nonhealing wounds. Wounds: A Compendium of Clinical Research & Practice. 2000;12(3):60-67. Not conducted in home setting or outpatient setting
61 Kairinos N, Hudson D, Solomons M. Depth of penetration of negative pressure wound therapy into underlying tissues. Wound Repair Regen. May-Jun. 2009;17(3):456. [pmid: 19660055]. No original data
62 Karatepe O, Eken I, Acet E, et al. Vacuum assisted closure improves the quality of life in patients with diabetic foot. Acta Chir Belg. Sep-Oct. 2011;111(5):298-302. [pmid: 22191131]. Not conducted in home setting or outpatient setting
63 Kim BS, Choi WJ, Baek MK, et al. Limb salvage in severe diabetic foot infection. Foot Ankle Int. Jan. 2011;32(1):31-37. [pmid: 21288432]. Not conducted in home setting or outpatient setting, Does not have a comparison group
64 Koehler C, Niederbichler AD, Jung FJ, et al. Wound therapy using the vacuum-assisted closure device: clinical experience with novel indications. J Trauma. Sep. 2008;65(3):722-731. discussion 31. [pmid: 18784590]. Sample size less than 20 subjects, Does not evaluate patients with chronic wounds, Not conducted in home setting or outpatient setting
65 Kurihara T, Kuwahara Y, Ichioka S. Analysis of the factors contributing to the outcome of negative pressure wound therapy. Wound Repair and Regeneration. 2013;21(1):A10. Meeting abstract, Does not apply to key questions
66 Kutovoi AB, Kosul'nikov SO, Tarnopol'skii SA, et al. Treatment of purulent wounds using vacuum-therapy. Klin Khir. Jun. 2011;(6):59-61. [pmid: 21846036]. Not in English and unable to determine eligibility
67 Labler L, Oehy K. Vacuum sealing of problem wounds. Swiss Surg. 2002;8(6):266-272. [pmid: 12520846]. Not in English and unable to determine eligibility
68 Langer V, Bhandari PS, Rajagopalan S, et al. Negative pressure wound therapy as an adjunct in healing of chronic wounds. Int Wound J. 2013. Jul. 16. [pmid: 23855645]. Not conducted in home setting or outpatient setting, Does not have a comparison group
69 Lantis J, Gendics C, Schwartz J, et al. Negative pressure wound therapy with instillation (npwti) better reduces post debridement bioburden in chronically infected lower extremity wounds than npwt alone. EWMA journal. 2013:106. abstract no. 72. Meeting abstract, Sample size less than 20 subjects
70 Larichev AB, Antoniuk AV, Kuz'min VS. Vacuum-therapy in treatment of festering wounds. Khirurgiia (Mosk). 2008;(6):22-26. [pmid: 18577940]. Not in English and unable to determine eligibility
71 Lavery LA, Barnes SA, Keith MS, et al. Prediction of healing for postoperative diabetic foot wounds based on early wound area progression. Diabetes Care. Jan. 2008;31(1):26-29. [pmid: 17934156]. Does not apply to key questions
72 Lee DL, Ryu AY, Rhee SC. Negative pressure wound therapy: an adjuvant to surgical reconstruction of large or difficult skin and soft tissue defects. Int Wound J. Aug. 2011;8(4):406-411. [pmid: 21595830]. No original data, Does not have a comparison group
73 Lee SS, Chang KP, Lai CS, et al. Does continuous negative-pressure and irrigation treatment really rinse the whole closed wound?. Plast Reconstr Surg. Jul. 2008;122(1):319-320. author reply 20-1. [pmid: 18594434]. No original data, Sample size less than 20 subjects
74 Lei L, Yan W, Chen K. Designing of the two-way suction drainage tube in vacuum sealing. Zhongguo Yi Liao Qi Xie Za Zhi. Jan. 2012;36(1):39-40. [pmid: 22571151]. Not in English and unable to determine eligibility, Does not apply to key questions
75 Li TS, Choong MY, Wu HF, et al. Simplified negative-pressure wound therapy system for skin graft wounds. Plast Reconstr Surg. Feb. 2012;129(2):399e-401e. [pmid: 22495212]. Sample size less than 20 subjects, Does not evaluate patients with chronic wounds
76 Lutsenko SM, Kalugin AS. The treatment of trophic ulcers of the lower extremities by application of preserved heterogenic peritoneum and vacuum therapy. Ortop Travmatol Protez. 1965;26:26-29. [pmid: 14279277]. Not in English and unable to determine eligibility
77 Maggio G, Armenio A, Pascone M. Bio-engineered tissue and vac therapy: A new method for the treatment of the wide soft tissue defects in the diabetic foot. European Journal of Clinical Investigation. 2010;40:87. [pmid: 19912317]. Meeting abstract, Unable to abstract relevant data
78 Maguina P, Kalimuthu R. Posterior rectal hernia after vacuum-assisted closure treatment of sacral pressure ulcer. Plast Reconstr Surg. Jul. 2008;122(1):46e-47e. [pmid: 18594380]. No original data, Sample size less than 20 subjects
79 Mendez-Eastman S. Determining the appropriateness of negative pressure wound therapy for pressure ulcers. Ostomy Wound Manage. Apr. 2004;50(4A Suppl):13-16. [pmid: 15317238]. No original data
80 Mendonca DA, Drew PJ, Harding KG, et al. A pilot study on the effect of topical negative pressure on quality of life. J Wound Care. Feb. 2007;16(2):49-53. [pmid: 17319616]. Sample size less than 20 subjects, Does not evaluate patients with chronic wounds, Does not have a comparison group
81 Mert M, Karatepe O, Eken I, et al. The affect of Vacuum Assisted closure on the quality of life in patients with diabetic foot. Diabetes. 2009;58. Meeting abstract
82 Miller MS, McDaniel C. Treating wound dehiscence with an alternative system of delivering topical negative pressure. J Wound Care. Jul. 2006;15(7):321-324. [pmid: 16869201]. Sample size less than 20 subjects
83 Miller MS, Whinney R, McDaniel C. Treating a nonhealing wound with negative pressure wound therapy. Adv Skin Wound Care. May. 4. 2006;19(4):202-5. [pmid: 16641566]. Sample size less than 20 subjects, Does not have a comparison group
84 Mirazimow BM. Preparation of wounds and abscesses for dermatoplasty by means of a vacuum device. Beiträge zur Orthopädie und Traumatologie. 1967;14(4):224-230. [pmid: 4869384]. Not in English and unable to determine eligibility, Does not evaluate patients with chronic wounds
85 Mirsaidi N. Negative pressure wound therapy: Use with care. Nursing. Sep. 2010;40(9):64-66. [pmid: 20714258]. No original data
86 MJ. Vacuum-assisted closure: a new method for wound control and treatment: clinical experience. Ann Plast Surg. Jun. 1997;38(6):563-576. discussion 77. [pmid: 9188971]. Does not have a comparison group
87 Moues CM, Bemd G, Meerding WJ, et al. Cost analysis comparing vacuum-assisted closure wound therapy to conventional moist gauze therapy. 2nd World Union of Wound Healing Societies Meeting. 2004, 8–13 July. Paris. 2004:87. Abstract no. A0008. Other- Meeting abstract only
88 Moues CM, van den Bemd GJ, Heule F, et al. Comparing conventional gauze therapy to vacuum-assisted closure wound therapy: a prospective randomised trial. J Plast Reconstr Aesthet Surg. Does not evaluate patients with chronic wounds
89 Moues CM, Vos MC, van den Bemd GJ, et al. Bacterial load in relation to vacuum-assisted closure wound therapy: a prospective randomized trial. Wound Repair Regen. Jan-Feb. 2004;12(1):11-17. [pmid: 14974959]. Not conducted in home setting or outpatient setting
90 Mullner T, Mrkonjic L, Kwasny O, et al. The use of negative pressure to promote the healing of tissue defects: a clinical trial using the vacuum sealing technique. Br J Plast Surg. Apr. 1997;50(3):194-199. [pmid: 9176007]. Device not available in the US/not FDA approved, Does not have a comparison group
91 Nain PS, Uppal SK, Garg R, et al. Role of negative pressure wound therapy in healing of diabetic foot ulcers. J Surg Tech Case Rep. Jan. 2011;3(1):17-22. [pmid: 22022649]. Not conducted in home setting or outpatient setting
92 Nakayama M. Applying negative pressure therapy to deep pressure ulcers covered by soft necrotic tissue. Int Wound J. Jun. 2010;7(3):160-166. [pmid: 20455957]. Not conducted in home setting or outpatient setting, Does not have a comparison group
93 Nakayama M. Variations of negative pressure wound therapy. J Surg Tech Case Rep. Jan. 2011;3(1):12. [pmid: 22022647]. No original data, Sample size less than 20 subjects
94 Nather A. Role of negative pressure wound therapy in healing of diabetic foot ulcers. J Surg Tech Case Rep. Jan. 2011;3(1):10-11. [pmid: 22022646]. No original data, Sample size less than 20 subjects
95 Negative pressure wound therapy: Executive summary of final report N04-03, Version 1.0. Institute for Quality and Efficiency in Health Care: Executive Summaries. Cologne, Germany. IQWiG (Institute for Quality and Efficiency in Health Care). 2005. No original data
96 Niezgoda JA. A comparison of vacuum assisted closure therapy to moist wound care in the treatment of pressure ulcers: preliminary results of a multicenter trial. 2nd World Union of Wound Healing Societies Meeting. 2004, 8–13 July. Paris. 2004:53. Other- unable to retrieve article
97 Niezgoda JA. Incorporating negative pressure therapy into the management strategy for pressure ulcers. Ostomy Wound Manage. Nov. 2004;50(11A Suppl):5S-8S. [pmid: 15632459]. No original data, Sample size less than 20 subjects, Does not have a comparison group
98 Nikolov A. Vacuum treatment method in postphlebitic and varicose trophic ulcers of the lower extremities. Khirurgiia (Mosk). 1981;34(4):368-371. Device not available in the US/not FDA approved, Unable to abstract relevant data
99 Obolenskiy V, Ermolov A, Sychev D, et al. Clinical and economic effectiveness of the negative pressure wound therapy in acute and chronic wounds treatment. EWMA journal. 2013:103. abstract no. 67. Meeting abstract, Not conducted in home setting or outpatient setting
100 Otterbourg K. The healing machine. Fortune. Nov. 12. 2012;166(8):146-149. 51. 52. 54 passim. [pmid: 23227708]. No original data, Does not evaluate patients with chronic wounds, Does not have a comparison group, Does not apply to key questions
101 Ousey K, Milne J. Focus on negative pressure: exploring the barriers to adoption. Br J Community Nurs. Mar. 2010;15(3):121-124. [pmid: 20220627]. No original data, Does not evaluate patients with chronic wounds
102 Ousey KJ, Milne J, Cook L, et al. A pilot study exploring quality of life experienced by patients undergoing negative pressure wound therapy as part of their wound care treatment compared to patients receiving standard wound care. Int Wound J. 2012. Oct. 24. [pmid: 23095095]. Does not evaluate patients with chronic wounds
103 Page JC, Newswander B, Schwenke DC, et al. Negative pressure wound therapy in open foot wounds with significant soft tissue defects. Ostomy Wound Manage. Feb. 2005;51(2A Suppl):9S-14S. [pmid: 15699558]. Does not evaluate patients with chronic wounds
104 Page JC, Newswander B, Schwenke DC, et al. Retrospective analysis of negative pressure wound therapy in open foot wounds with significant soft tissue defects. Adv Skin Wound Care. Sep. 2004;17(7):354-364. [pmid: 15343085]. Does not evaluate patients with chronic wounds, Not conducted in home setting or outpatient setting
105 Panicker VN. A pilot study evaluating topical negative pressure using V1STA® technology. Wound Practice & Research. 2009;17(4):194-200. Not conducted in home setting or outpatient setting, Does not have a comparison group
106 Pataia E, Arleo S, Somma F, et al. Use of biotechnologies in cutaneous injuries limb repair. European Surgical Research. 2010;45(3–4):228. Meeting abstract, Unable to abstract relevant data
107 Penny HL, Dyson M, Spinazzola J, et al. The use of negative-pressure wound therapy with bio-dome dressing technology in the treatment of complex diabetic wounds. Adv Skin Wound Care. Jul. 2010;23(7):305-312. [pmid: 20562538]. Sample size less than 20 subjects, Does not have a comparison group
108 Philbeck TE Jr, Schroeder WJ, Whittington KT. Vacuum-assisted closure therapy for diabetic foot ulcers: clinical and cost analyses. Home Health Care Consultant. 2001;8(3):27. Does not have a comparison group
109 Philbeck TE Jr, Whittington KT, Millsap MH, et al. The clinical and cost effectiveness of externally applied negative pressure wound therapy in the treatment of wounds in home healthcare Medicare patients. Ostomy Wound Manage. Nov. 1999;45(11):41-50. [pmid: 10687657]. Does not report an outcome of interest
110 Pigg B. The implications of the current environment for wound care product development. Int J Low Extrem Wounds. Dec. 2011;10(4):184-185. [pmid: 22184749]. No original data
111 Pignatti M, Bruti M, Rigotti G. Mobile-VAC for the treatment of lower limb ulcers. Plast Reconstr Surg. Nov. 2001;108(6):1837-1838. [pmid: 11711994]. No original data, Sample size less than 20 subjects, Device not available in the US/not FDA approved, Does not evaluate patients with chronic wounds
112 Pruksapong C. Efficacy of portable vacuum dressing in chronic wound care: a prospective randomized control trial. J Med Assoc Thai. Oct. 2011;94(10):1212-1217. [pmid: 22145506]. Device not available in the US/not FDA approved, Not conducted in home setting or outpatient setting
113 Rahmanian-Schwarz A, Willkomm LM, Gonser P, et al. A novel option in negative pressure wound therapy (NPWT) for chronic and acute wound care. Burns. Jun. 2012;38(4):573-577. [pmid: 22100423]. Not conducted in home setting or outpatient setting, Sample size less than 20 subjects
114 Rannou F. Scarification and vacuum application in non-specific low back pain: The first RCT in a primary care setting - Commentary. Focus on Alternative and Complementary Therapies. 2009;14(2):122-123. Unable to abstract relevant data
115 Ravari H, Modaghegh MH, Kazemzadeh GH, et al. Comparision of vacuum-asisted closure and moist wound dressing in the treatment of diabetic foot ulcers. J Cutan Aesthet Surg. Jan. 2013;6(1):17-20. [pmid: 23723599]. Not conducted in home setting or outpatient setting, Does not report an outcome of interest
116 Reeder S, de Roos KP, de Maeseneer M, et al. Ulcer recurrence after in-hospital treatment for recalcitrant venous leg ulceration. Br J Dermatol. May. 2013;168(5):999-1002. [pmid: 23253015]. Does not evaluate patients with chronic wounds
117 Riaz MU, Khan MUR, Akbar A. Comparison of vacuum assisted closure versus normal saline dressing in healing diabetic wounds. Pakistan Journal of Medical and Health Sciences. 2010;4(4). Device not available in the US/not FDA approved, Not conducted in home setting or outpatient setting
118 Ritchey ME, Sansing VV, Domurat R, et al. Pain and hemorrhage with negative pressure wound therapy: Inpatient and non-inpatient experience. Pharmacoepidemiology and Drug Safety. 2011;20:S40. Meeting abstract, Not conducted in home setting or outpatient setting, Does not apply to key questions
119 Robinson CG. Complex stage iv pressure ulcers heal at home with a combination of negative pressure wound therapy and pulsed radio frequency energy. Journal of Wound, Ostomy & Continence Nursing. 2011;38(3S):S14-S. Meeting abstract, Not conducted in home setting or outpatient setting
120 Rogers LC, Andros G. Competitive bidding for negative pressure wound therapy: what will it mean to you?. Ostomy Wound Manage. Dec. 2011;57(12):48. [pmid: 22263255]. No original data
121 Saiid R. TeleHomecare and negative pressure wound therapy: a novel approach to wound management in the home. Remington Report. 2001;9(2):36-38. No original data, Does not have a comparison group
122 Saleh DB, Jivan S. Drain use in conjunction with vacuum assisted wound closure. J Plast Reconstr Aesthet Surg. Apr. 2012;65(4):540-541. [pmid: 22030079]. No Original Data
123 Sames CP. Sealing of wounds with vacuum drainage. British medical journal. 1977;2(6096):1123. No original data, Device not available in the US/not FDA approved
124 Sandison S. Negative pressure wound therapy promoted healing of diabetic foot ulcers more than advanced moist wound therapy. Evid Based Nurs. Oct. 2008;11(4):116. [pmid: 18815328]. No original data
125 Sibbald RG, Woo KY. V.A.C. therapy in home care. Int Wound J. Jun. Suppl 2. 2008;5:iii-iv. [pmid: 18577131]. No original data
126 Sjogren J, Gustafsson R, Lindstedt S, et al. Vacuum-assisted closure yields good clinical results. Good healing in complicated wounds--deep sternal infections an example. Lakartidningen. Oct. 1–7. 2008;105(40):2773-2276. [pmid: 18953789]. No original data, Not in English and unable to determine eligibility
127 Smith N. The benefits of VAC therapy in the management of pressure ulcers. Br J Nurs. 12. 2004;13(22):1359-1365. Dec 9-2005 Jan. [pmid: 15687905]. No original data
128 Soares MO, Bojke L, Dumville J, et al. Methods to elicit experts' beliefs over uncertain quantities: application to a cost effectiveness transition model of negative pressure wound therapy for severe pressure ulceration. Stat Med. Aug. 30. 2011;30(19):2363-2380. [pmid: 21748773]. Does not apply to key questions
129 Stansby G, Wealleans V, Wilson L, et al. Clinical experience of a new NPWT system in diabetic foot ulcers and post-amputation wounds. J Wound Care. Nov. 8. 2010;19(11):496-502. [pmid: 21135798]. Does not have a comparison group
130 Stechmiller JK, Kilpadi DV, Childress B, et al. Effect of Vacuum-Assisted Closure Therapy on the expression of cytokines and proteases in wound fluid of adults with pressure ulcers. Wound Repair Regen. May-Jun. 2006;14(3):371-374. [pmid: 16808818]. No original data
131 Sun JW, Sun JH, Zhang CC. Vacuum assisted closure technique for repairing diabetic foot ulcers: Analysis of variance by using a randomized and double-stage crossover design. Journal of Clinical Rehabilitative Tissue Engineering Research. 2007:8908-8911. Not in English and unable to determine eligibility
132 Tan D, Rajanayagam J, Schwarz F. Treatment of long-standing, poor-healing diabetic foot ulcers with topical negative pressure in the Torres Strait. Aust J Rural Health. Aug. 2007;15(4):275-276. [pmid: 17617094]. Does not have a comparison group
133 Tatu RF, Brediceanu R, Ungurean C, et al. Infected wound treatment using negative pressure atmosphere. Chirurgia (Bucur). Sep-Oct. 2007;102(5):577-580. [pmid: 18018359]. No original data, Not in English and unable to determine eligibility
134 Tauro LF, Ravikrishnan J, Rao BSS, et al. A comparative study of the efficacy of topical negative pressure moist dressings and conventional moist dressings in chronic wounds. Indian Journal of Plastic Surgery. 2007:133-140. Not conducted in home setting or outpatient setting
135 Tellez R, Arano C, Corominas A, et al. Negative pressure therapy for venous ulcers. Anales de Cirugia Cardiaca y Vascular. 2006;12(2):83-85. Not in English and unable to determine eligibility
136 Tuncel U, Erkorkmaz U, Turan A. Clinical evaluation of gauze-based negative pressure wound therapy in challenging wounds. Int Wound J. Apr. 2013;10(2):152-158. [pmid: 22420837]. Not conducted in home setting or outpatient setting
137 Udell E. Negative-pressure wound therapy and diabetic foot amputations: a retrospective study of Payer Claims Data. J Am Podiatr Med Assoc. Mar-Apr. 2008;98(2):164-165. author reply 5. [pmid: 18347130]. No original data
138 Vuerstaek JD, Vainas T, Wuite J, et al. State-of-the-art treatment of chronic leg ulcers: A randomized controlled trial comparing vacuum-assisted closure (V.A.C.) with modern wound dressings. J Vasc Surg. Nov. 2006;44(5):1029-1037. discussion 38. [pmid: 17000077]. Not conducted in home setting or outpatient setting
139 Wallin AM, Bostrom L, Ulfvarson J, et al. Negative pressure wound therapy - a descriptive study. Ostomy Wound Manage. Jun. 2011;57(6):22-29. [pmid: 21701045]. Not conducted in home setting or outpatient setting, Does not have a comparison group
140 Wanner MB, Schwarzl F, Strub B, et al. Vacuum-assisted wound closure for cheaper and more comfortable healing of pressure sores: a prospective study. Scand J Plast Reconstr Surg Hand Surg. 2003;37(1):28-33. [pmid: 12625392]. Not conducted in home setting or outpatient setting
141 Weir D, Blakely M. The impact of a unique new disposable negative pressure wound therapy device on patient tolerance of therapy and quality of life. Journal of Wound, Ostomy & Continence Nursing. 2011;38(3S):S19-S. Meeting abstract, Does not apply to key questions
142 Welt K, Hinrichs R, Weiss JM, et al. Wound healing. European Journal of Dermatology. 2009;19(4):413-416. [pmid: 19574192]. No original data
143 Wild T, Sahora K, Renner B, et al. Digital monitoring of V.A.C.(registered trademark) therapy. European Surgery - Acta Chirurgica Austriaca. SUPPL 191. 2003;35:44-46. Not in English and unable to determine eligibility, Does not evaluate patients with chronic wounds
144 Witkowski W. A prospective clinical evaluation of a topical negative pressure wound therapy system in the resolution and management of complex wounds. World Council of Enterostomal Therapists Journal. 2009;29(4):30. Meeting abstract, Not conducted in home setting or outpatient setting, Unable to abstract relevant data
145 Wiwanitkit V. Vacuum-assisted Closure and Moist Wound Dressing in Diabetic Foot. J Cutan Aesthet Surg. Jul. 2013;6(3):173. [pmid: 24163542]. No original data
146 Wollina U. One-stage Reconstruction of Soft Tissue Defects with the Sandwich Technique: Collagen-elastin Dermal Template and Skin Grafts. J Cutan Aesthet Surg. Sep. 2011;4(3):176-182. [pmid: 22279382]. Device not available in the US/not FDA approved, Does not evaluate patients with chronic wounds, Does not have a comparison group, Unable to abstract relevant data
147 Wolvos T. Wound instillation with negative pressure wound therapy. Ostomy Wound Manage. Feb. 2005;51(2A Suppl):21S-26S. [pmid: 15699560]. Does not have a comparison group
148 Xie T, Lu S, Mani R. Diabetic foot infection in the world: - We need ways forward. Int J Low Extrem Wounds. Mar. 2010;9(1):3-5. [pmid: 20207615]. No original data
149 Xu HD, Zhao JN, Lu JH, et al. Application of clearance flush vacuum-sealing drainage based on wound dressing in chronic wounds. Chinese Journal of Tissue Engineering Research. 2013;17(16):3026-3032. Not in English and unable to determine eligibility
150 Zhang C, Yang JC, Feng YQ, et al. Clinical observations of negative pressure wound therapy and basic fibroblast growth factor in the treatment of intractable pressure ulcer. Zhonghua Yi Xue Za Zhi. Oct. 30. 2012;92(40):2862-2864. [pmid: 23290219]. Not in English and unable to determine eligibility, Does not report an outcome of interest
151 Zhong M, Yan XD, Xu GL, et al. Negative pressure wound therapy and biological semipermeable membrane covering for the treatment of diabetic skin chronic ulcers. Chinese Journal of Tissue Engineering Research. 2012;16(43):8152-8158. Not conducted in home setting or outpatient setting