# Forms

Abstract Review Form

The abstract review form is shown from the Distiller SR online software program. The abstract, title, and authors are displayed. Next to them are exclusion criteria to checkbox, as well as unclear, include, pull for handsearch, and a comment box.

Article Review Form

The article review form is shown from the Distiller SR online software program. The abstract, title, and authors are displayed. Next to them are exclusion criteria to checkbox, as well as include, pull for handsearch, and a comment box.

Data Abstraction Form: Key Question 2 and 4

The data abstraction form for key question 2 and 4 is shown from the Systematic Review Data Repository (SRDR) on the Agency for Healthcare Research and Quality (AHRQ) website. Key questions 2 and 4 is shown, then there are sections with various checkboxes, radio buttons, fill ins, dropdown menus, and comments boxes to answer questions that describe characteristics of the article being reviewed pertaining to key questions 2 and 4. There are arm name suggestions, then arm details, design details and enrollment, baseline characteristics fields, and outcome name suggestions with list of outcome titles. Next is outcome details, adverse events, and quality dimension fields from the Cochrane Risk of Bias Tool and overall rating of the study

Data Abstraction Form: Key Question 3

The data abstraction form for key question 3 is shown from the Systematic Review Data Repository (SRDR) on the Agency for Healthcare Research and Quality (AHRQ) website. Key question 3 is shown, then there are sections with various checkboxes, radio buttons, fill ins, dropdown menus, and comments boxes to answer questions that describe characteristics of the article being reviewed pertaining to key question 3. There are arm name suggestions, then arm details, design details and enrollment, baseline characteristics fields, and outcome name suggestions with list of outcome titles. Next is outcome details, adverse events, and quality dimension fields from the Cochrane Risk of Bias Tool and overall rating of the study.