# Detailed Electronic Database Search Strategies

PubMed Strategy

Search | String | Hits
#1 | “wound healing”[mh] | 91953
#2 | “skin ulcer”[mh] | 34694
#3 | “wounds and injuries”[mh:noexp] | 62378
#4 | Wound*[tiab] | 133934
#5 | Ulcer*[tiab] | 161431
#6 | #1 OR #2 OR #3 OR #4 OR #5 | 407104
#7 | Vacuum[mh] | 3623
#8 | Suction[mh] | 10280
#9 | “Negative-pressure wound therapy”[mh] | 1292
#10 | “negative pressure”[tiab] OR “negative-pressure”[tiab] | 5831
#11 | “vacuum assisted”[tiab] OR “vacuum-assisted”[tiab] | 2081
#12 | “subatmospheric”[tiab] OR “sub-atmospheric”[tiab] | 467
#13 | “vacuum sealing”[tiab] OR “vacuum sealed”[tiab] OR “vacuum-sealed”[tiab] | 219
#14 | #7 OR #8 OR #9 OR #10 OR #11 OR #12 OR #13 | 20971
#15 | Animals[mh] NOT humans[mh] | 3900404
#16 | (#6 AND #14) NOT #15 | 2886

Embase Strategy

Search | String | Hits
#1 | 'wound healing'/exp | 118248
#2 | 'wound care'/exp | 65077
#3 | 'skin ulcer'/exp | 50849
#4 | Wound*:ti,ab | 162317
#5 | Ulcer*:ti,ab | 204536
#6 | #1 OR #2 OR #3 OR #4 OR #5 | 462438
#7 | 'Vacuum'/exp | 27769
#8 | 'vacuum assisted closure'/exp | 3384
#9 | “negative pressure”:ti,ab OR “negative-pressure”:ti,ab | 6807
#10 | “vacuum assisted”:ti,ab OR “vacuum-assisted”:ti,ab | 2580
#11 | “subatmospheric”:ti,ab OR “sub-atmospheric”:ti,ab | 521
#12 | “vacuum sealing”:ti,ab OR “vacuum sealed”:ti,ab OR “vacuum-sealed”:ti,ab | 254
#13 | #7 OR #8 OR #9 OR #10 OR #11 OR #12 | 33384
#14 | #6 AND #13 | 4552
#15 | 'Animal'/exp NOT 'human'/exp | 4332414
#16 | #14 NOT #15 | 4321

The Cochrane Central Register of Controlled Trials (CENTRAL) Strategy

Search | String | Hits
#1 | MeSH descriptor: [Wound Healing] explode all trees | 4431
#2 | MeSH descriptor: [Skin Ulcer] explode all trees | 1851
#3 | MeSH descriptor: [Wounds and Injuries] this term only | 1271
#4 | Wound*:ti,ab,kw | 14058
#5 | Ulcer*:ti,ab,kw | 15012
#6 | #1 OR #2 OR #3 OR #4 OR #5 | 28134
#7 | MeSH descriptor: [Vacuum] explode all trees | 131
#8 | MeSH descriptor: [Suction] explode all trees | 786
#9 | MeSH descriptor: [Negative-Pressure Wound Therapy] explode all trees | 108
#10 | “negative pressure”:ti,ab,kw OR “negative-pressure”:ti,ab,kw | 575
#11 | “vacuum assisted”:ti,ab,kw OR “vacuum-assisted”:ti,ab,kw | 157
#12 | “subatmospheric”:ti,ab,kw OR “sub-atmospheric”:ti,ab,kw | 22
#13 | “vacuum sealing”:ti,ab,kw OR “vacuum sealed”:ti,ab,kw OR “vacuum-sealed”:ti,ab,kw | 14
#14 | #7 OR #8 OR #9 OR #10 OR #11 OR #12 OR #13 | 1519
#15 | (#6 AND #14) | 364
| Only trials | 269

CINAHL Strategy

Search | String | Hits
#1 | MH “Skin ulcer+” | 17319
#2 | MH “Wounds, chronic” | 1843
#3 | TX Wound* | 57694
#4 | TX Ulcer* | 23253
#5 | S1 OR S2 OR S3 OR S4 | 72361
#6 | MH Vacuum+ | 197
#7 | MH Suction+ | 1836
#8 | MH “Negative Pressure Wound Therapy” | 952
#9 | TX “negative pressure” OR TX “negative-pressure” | 1615
#10 | TX “vacuum assisted” OR TX “vacuum-assisted” | 434
#11 | TX “subatmospheric” OR TX “sub-atmospheric” | 44
#12 | TX “vacuum sealing” OR TX “vacuum sealed” OR TX “vacuum-sealed” | 6
#13 | S6 OR S7 OR S8 OR S9 OR S10 OR S11 OR S12 | 3667
#14 | (S5 AND S13) | 1486

ClinicalTrials.gov Strategy

Search | String | Hits
#1 | Negative pressure wound therapy | 93