# List of Abbreviations

AHRQ: Agency for Healthcare Research and Quality
CAG: Coverage and Analysis Group
CI: Confidence interval
CINAHL: Cumulative Index to Nursing and Allied Health Literature
CMS: Centers for Medicare and Medicaid services
CPT: Current Procedural Terminology
FDA: Food and Drug Administration
ICD: International Classification of Diseases
KCI: Kinetic Concepts Inc.
KM: Kaplan-Meier
KQ: Key question
MeSH: Medical subject headings
MRI: Magnetic Resonance Imaging
N: Number
NA: Not available
NPUAP: National Pressure Ulcer Advisory Panel
NPWT: Negative pressure wound therapy
NR: Not reported
PICOTS: Population, intervention, comparison, outcome, timing, setting
RCT: Randomized controlled trial
S&N: Smith and Nephew
SD: Standard deviation
SNaP: Smart Negative Pressure Wound Care System
SRDR: Systematic Review Data Repository
U.S.: United States
V.A.C.: Vacuum Assisted Closure