# Acknowledgments

We would like to thank Oluwaseun Shogbesan for her assistance in reviewing articles and Faye Rivken for copy editing. We would also like to thank the Peer Reviewers, the Task Order Officer, and representatives from CMS.

## Peer Reviewers

We wish to acknowledge individuals listed below for their review of this report. This report has been reviewed in draft form by individuals chosen for their expertise and diverse perspectives. The purpose of the review was to provide candid, objective, and critical comments for consideration by the EPC in preparation of the final report. Synthesis of the scientific literature presented here does not necessarily represent the views of individual reviewers.

- Jiyoung M. Dang, Ph.D.
  Supervisory Biomedical Engineering
  Food and Drug Administration
  Silver Spring, MD
- William Li, M.D.
  President and Medical Director
  The Angiogenesis Foundation
  Cambridge, MA
- Paul Y. Liu, M.D.
  Chair, Department of Plastic and Reconstructive Surgery
  Brown University
  Providence, RI
- Nasrin Mirsaidi, R.N., M.S.N., C.N.O.R.
  Physical Scientist
  Food and Drug Administration
  Silver Spring, MD
- Simon Palfreyman, B.Sc., R.G.N., M.Sc., Ph.D.
  Clinical Lecturer
  Sheffield Teaching Hospitals NHS
  Foundation Trust/University of Sheffield
  Sheffield, UK
- Jeffrey M. Robbins, D.P.M.
  Director, Podiatry Service VACO
  Louis Stokes Cleveland VAMC
  Cleveland, OH
- Karen Schoelles, M.D., S.M.
  Director, ECRI Institute-Penn Medicine
  Evidence-based Practice Center
  ECRI Institute
  Plymouth Meeting, PA
- Terry Treadwell, M.D., F.A.C.S.
  Medical Director
  Institute for Advanced Wound Care
  Montgomery, AL