# References

1 Lazarus GS, Cooper DM, Knighton DR, Margolis DJ, Pecoraro RE, Rodeheaver G, et al. Definitions and guidelines for assessment of wounds and evaluation of healing. Arch Dermatol. Apr. 1994;130(4):489-493. [pmid: 8166487].
2 Walmsley S. Advances in wound management: Executive summary. Clinica Reports. London. PBJ Publications Ltd. 2002.
3 Sen CK, Gordillo GM, Roy S, Kirsner R, Lambert L, Hunt TK, et al. Human skin wounds: a major and snowballing threat to public health and the economy. Wound repair and regeneration : official publication of the Wound Healing Society [and] the European Tissue Repair Society. Nov-Dec. 2009;17(6):763-771.
4 Fonder MA, Lazarus GS, Cowan DA, Aronson-Cook B, Kohli AR, Mamelak AJ. Treating the chronic wound: A practical approach to the care of nonhealing wounds and wound care dressings. Journal of the American Academy of Dermatology. 2008;58(2):185-206. [pmid: 18222318].
5 Bergqvist D, Lindholm C, Nelzen O. Chronic leg ulcers: the impact of venous disease. J Vase Surg. Apr. 1999;29(4):752-755.
6 Morbach S, Furchert H, Groblinghoff U, Hoffmeier H, Kersten K, Klauke GT, et al. Long-term prognosis of diabetic foot patients and their limbs: amputation and death over the course of a decade. Diabetes Care. Oct. 2012;35(10):2021-207. [pmid: 22815299].
7 Margolis DJ, Bilker W, Santanna J, Baumgarten M. Venous leg ulcer: incidence and prevalence in the elderly. Journal of the American Academy of Dermatology. Mar. 2002;46(3):381-386. [pmid: 11862173].
8 Margolis DJ, Bilker W, Knauss J, Baumgarten M, Strom BL. The incidence and prevalence of pressure ulcers among elderly patients in general medical practice. Annals of epidemiology. Jul. 2002;12(5):321-325. [pmid: 12062919].
9 Centers for Disease Control and Prevention. Crude and Age-Adjusted Incidence of Diagnosed Diabetes per 1000 Population Aged 18–79 Years, United States, 1980–2011. 2012. cited 2014 August 13. Available from: http://www.cdc.gov/diabetes/statistics/incidence/fig2.htm.
10 Centers for Disease Control and Prevention. Number (in Millions) of People with Diabetes Aged 35 Years or Older with Self-Reported Heart Disease or Stroke, United States, 1997–2011. 2012.
11 Levinson DR. Comparison of Prices for Negative Pressure Wound Therapy Pumps. Washington, DC. Office of Inspector General. 2009. Contract No.: OEI-02-07-00660.
12 Negative pressure wound therapy: an evidence-based analysis. Ont Health Technol Assess Ser. 2006;6(14):1-38.
13 Centers for Medicare and Medicaid Services. Local Coverage Determination (LCD): Negative Pressure Wound Therapy Pumps (L5008). 2011. Available at: http://www.cms.gov.
14 Plikaitis CM, Molnar JA. Subatmospheric pressure wound therapy and the vacuum- assisted closure device: basic science and current clinical successes. Expert Rev Med Devices. Mar. 2006;3(2):175-184. [pmid: 16515384].
15 Morykwas MJ, Argenta LC, Shelton-Brown El, McGuirt W. Vacuum-assisted closure: a new method for wound control and treatment: animal studies and basic foundation. Ann Plast Surg. Jun. 1997;38(6):553-562. [pmid: 9188970].
16 Schintler MV. Negative pressure therapy: theory and practice. Diabetes Metab Res Rev. Feb. Suppl 1. 2012;28:72-77. [pmid: 22271727].
17 Scherer SS, Pietramaggiori G, Mathews JC, Prsa MJ, Huang S, Orgill DP. The mechanism of action of the vacuum-assisted closure device. Plast Reconstr Surg. 2008;122(3):786-797. [pmid: 18766042].
18 Erba P, Ogawa R, Ackermann M, Adini A, Miele LF, Dastouri P, et al. Angiogenesis in wounds treated by microdeformational wound therapy. Ann Surg. 2011;253(2):402-409. [pmid: 21217515].
19 Seo SG, Yeo JH, Kim JH, Kim JB, Cho TJ, Lee DY. Negative-pressure wound therapy induces endothelial progenitor cell mobilization in diabetic patients with foot infection or skin defects. Experimental & molecular medicine. 2013;45:e62. [pmid: 24232261].
20 Orgill DP, Manders EK, Sumpio BE, Lee RC, Attinger CE, Gurtner GC, et al. The mechanisms of action of vacuum assisted closure: more to learn. Surgery. Jul. 2009;146(1):40-51. [pmid: 19541009].
21 Lu F, Ogawa R, Nguyen DT, Chen B, Guo D, Helm DL, et al. Microdeformation of three-dimensional cultured fibroblasts induces gene expression and morphological changes. Ann Plast Surg. Mar. 2011;66(3):296-300. [pmid: 21233699].
22 Glass GE, Nanchahal J. The methodology of negative pressure wound therapy: separating fact from fiction. Journal of plastic, reconstructive & aesthetic surgery: JPRAS. Aug. 2012;65(8):989-1001.
23 Wu SC, Armstrong DG. Clinical outcome of diabetic foot ulcers treated with negative pressure wound therapy and the transition from acute care to home care. Int Wound J. Jun. Suppl 2. 2008;5:10-16. [pmid: 18577133].
24 Fraccalvieri M, Ruka E, Bocchiotti MA, Zingarelli E, Bruschi S. Patient's pain feedback using negative pressure wound therapy with foam and gauze. Int Wound J. Oct. 2011;8(5):492-499. [pmid: 21827628].
25 Orgill DP, Bayer LR. Update on negative-pressure wound therapy. Plast Reconstr Surg. Jan. Suppl 1. 2011;127:105S-115S. [pmid: 21200280].
26 Citak M, Backhaus M, Meindl R, Muhr G, Fehmer T. Rare complication after VAC-therapy in the treatment of deep sore ulcers in a paraplegic patient. Arch Orthop Trauma Surg. Dec. 2010;130(12):1511-1514. [pmid: 20306199].
27 Collinge C, Reddix R. The incidence of wound complications related to negative pressure wound therapy power outage and interruption of treatment in orthopaedic trauma patients. J Orthop Trauma. Feb. 2011;25(2):96-100. [pmid: 21245712].
28 van Wingerden JJ, Segers P, Jekel L. Major bleeding during negative pressure wound/V.A.C.(R)--therapy for postsurgical deep sternal wound infection--a critical appraisal. J Cardiothorac Surg. 2011;6:121. [pmid: 21955731].
29 Dessy LA, Serratore F, Corrias F, Parisi P, Mazzocchi M, Carlesimo B. Retention of polyurethane foam fragments during VAC therapy: a complication to be considered. Int Wound J. 2013. Apr. 17.
30 U.S. Food and Drug Administration. FDA Safety Communication: UPDATE on Serious Complications Associated with Negative Pressure Wound Therapy Systems. 2011. [May 19, 2014]; Available from: http://www.fda.gov/MedicalDevices/Safety/AlertsandNotices/ucm244211.htm.
31 Sullivan N, Snyder DL, Tipton K, Uhl S, Schoelles KM. Negative Pressure Wound Therapy Devices: Technology Assessement. Rockville, MD. Agency for Healthcare Research and Quality. 2009. WNDT1108.
32 Webster J, Scuffham P, Sherriff KL, Stankiewicz M, Chaboyer WP. Negative pressure wound therapy for skin grafts and surgical wounds healing by primary intention. The Cochrane database of systematic reviews. 2012;4:CD009261. [pmid: 22513974].
33 Trueman P, Flack S, Loonstra A, Hauser T. The feasibility of using V.A.C. Therapy in home care patients with surgical and traumatic wounds in the Netherlands. Int Wound J. Jun. 2008;5(2):225-231. [pmid: 18494628].
34 Berger P, de Bie D, Moll FL, de Borst GJ. Negative pressure wound therapy on exposed prosthetic vascular grafts in the groin. J Vasc Surg. Sep. 2012;56(3):714-720. [pmid: 22554424].
35 Baharestani MM, Gabriel A. Use of negative pressure wound therapy in the management of infected abdominal wounds containing mesh: an analysis of outcomes. Int Wound J. Apr. 2011;8(2):118-125. [pmid: 21176107].
36 Roberts DJ, Zygun DA, Grendar J, Ball CG, Robertson HL, Ouellet JF, et al. Negative-pressure wound therapy for critically ill adults with open abdominal wounds: a systematic review. The journal of trauma and acute care surgery. Sep. 2012;73(3):629-639. [pmid: 22929494].
37 Ubbink DT, Westerbos SJ, Evans D, Land L, Vermeulen H. Topical negative pressure for treating chronic wounds. The Cochrane database of systematic reviews. 2008;(3):CD001898. [pmid: 18646080].
38 Wanner MB, Schwarzl F, Strub B, Zaech GA, Pierer G. Vacuum-assisted wound closure for cheaper and more comfortable healing of pressure sores: a prospective study. Scand J Plast Reconstr Surg Hand Surg. 2003;37(1):28-33. [pmid: 12625392].
39 Khanbhai M, Fosah R, Oddy MJ, Richards T. Disposable NPWT device to facilitate early patient discharge following complex DFU. J Wound Care. Apr. 2012;21(4):180-182. [pmid: 22584676].
40 Armstrong DG, Lavery LA. Negative pressure wound therapy after partial diabetic foot amputation: a multicentre, randomised controlled trial. Lancet. Nov. 12. 2005;366(9498):1704-1710. [pmid: 16291063].
41 Gupta S, Ichioka S. Optimal use of negative pressure wound therapy in treating pressure ulcers. Int Wound J. Aug. Suppl 1. 2012;9:8-16. [pmid: 22727135].
42 Lau J, Tatsioni A, Balk E, Chew P, Kupelnick B, Wang C, et al. Usual Care in the Management of Chronic Wounds: A Review of the Recent Literature. Rockville, MD. Agency for Healthcare Research and Quality. 2005.
43 Trueman P. Cost-effectiveness considerations for home health V.A.C. Therapy in the United States of America and its potential international application. Int Wound J. Jun. Suppl 2. 2008;5:23-26. [pmid: 18577135].
44 Dowsett C, Davis L, Henderson V, Searle R. The economic benefits of negative pressure wound therapy in community-based wound care in the NHS. Int Wound J. Oct. 2012;9(5):544-552. [pmid: 22321132].
45 Moffatt CJ, Mapplebeck L, Murray S, Morgan PA. The experience of patients with complex wounds and the use of NPWT in a home-care setting. J Wound Care. Nov. 2011;20(11):512. 4. 6, passim. [pmid: 22240846].
46 Greer N, Foman NA, Macdonald R, Dorrian J, Fitzgerald P, Rutks I, et al. Advanced wound care therapies for nonhealing diabetic, venous, and arterial ulcers: a systematic review. Ann Intern Med. Oct. 15. 2013;159(8):532-542. [pmid: 24126647].
47 Dumville JC, Hinchliffe RJ, Cullum N, Game F, Stubbs N, Sweeting M, et al. Negative pressure wound therapy for treating foot wounds in people with diabetes mellitus. The Cochrane database of systematic reviews. 2013;10:CD010318. [pmid: 24132761].
48 Gottrup F, Apelqvist J, Price P. Outcomes in controlled and comparative studies on non-healing wounds: recommendations to improve the quality of evidence in wound management. J Wound Care. Jun. 2010;19(6):237-268. [pmid: 20551864].
49 Higgins JPT, Green S, editors. Cochrane handbook for systemic reviews of interventions Version 5.1.0. The Cochrane Collaboration. 2011. Oxford, England. Available at: http://handbook.cochrane.org.
50 Agency for Healthcare Research and Quality. Grading the Strength of a Body of Evidence When Assessing Health Care Interventions - AHRQ and the Effective Health Care Program: An Update. Rockville, MD. Agency for Healthcare Research and Quality. 2013. Available at: http://effectivehealthcare.ahrq.gov/ehc/products/457/1163/GradingTheStrengthofEvidence_DraftMethodsChapter_20120625.pdf.
51 Yao M, Fabbi M, Hayashi H, Park N, Attala K, Gu G, et al. A retrospective cohort study evaluating efficacy in high-risk patients with chronic lower extremity ulcers treated with negative pressure wound therapy. Int Wound J. 2012. Nov. 19.
52 Lerman B, Oldenbrook L, Eichstadt SL, Ryu J, Fong KD, Schubart PJ. Evaluation of chronic wound treatment with the SNaP wound care system versus modern dressing protocols. Plast Reconstr Surg. Oct. 2010;126(4):1253-1261. [pmid: 20885246].
53 Fife CE, Walker D, Thomson B, Otto G. The safety of negative pressure wound therapy using vacuum-assisted closure in diabetic foot ulcers treated in the outpatient setting. Int Wound J. Jun. Suppl 2. 2008;5:17-22. [pmid: 18577134].
54 Lavery LA, Boulton AJ, Niezgoda JA, Sheehan P. A comparison of diabetic foot ulcer outcomes using negative pressure wound therapy versus historical standard of care. Int Wound J. Jun. 2007;4(2):103-113. [pmid: 17651226].
55 Schwien T, Gilbert J, Lang C. Pressure ulcer prevalence and the role of negative pressure wound therapy in home health quality outcomes. Ostomy Wound Manage. Sep. 2005;51(9):47-60. [pmid: 16230764].
56 Ford CN, Reinhard ER, Yeh D, Syrek D, De Las Morenas A, Bergman SB, et al. Interim analysis of a prospective, randomized trial of vacuum-assisted closure versus the healthpoint system in the management of pressure ulcers. Ann Plast Surg. Jul. 2002;49(1):55-61. discussion. [pmid: 12142596].
57 Armstrong DG, Marston WA, Reyzelman AM, Kirsner RS. Comparison of negative pressure wound therapy with an ultraportable mechanically powered device vs. traditional electrically powered device for the treatment of chronic lower extremity ulcers: a multicenter randomized-controlled trial. Wound repair and regeneration : official publication of the Wound Healing Society [and] the European Tissue Repair Society. Mar-Apr. 2011;19(2):173-180.
58 Armstrong DG, Marston WA, Reyzelman AM, Kirsner RS. Comparative effectiveness of mechanically and electrically powered negative pressure wound therapy devices: a multicenter randomized controlled trial. Wound repair and regeneration : official publication of the Wound Healing Society [and] the European Tissue Repair Society. May-Jun. 2012;20(3):332-341.
59 Goeree R, Mahoney J, Sibbald G, Kitson M, Greco J. Negative Pressure Wound Therapy for the Treatment of Chronic Pressure Wounds. ClinicalTrials.gov [Internet]. 2011. cited 2014 March 18. Available from: http://ClinicalTrials.gov/show/NCT00691821.
60 Armstrong DG. SNaP Wound Care System Versus Traditional NPWT Device for Treatment of Chronic Wounds. ClinicalTrials.gov [Internet]. 2013. cited 2014 March 18. Available from: http://ClinicalTrials.gov/show/NCT00951080.
61 Guberman R. Efficacy Study of a Bioelectric Dressing Used With Negative Pressure Wound Therapy to Treat Diabetic and Pressure Ulcers. ClinicalTrials.gov [Internet]. 2012. cited 2014 March 18. Available from: http://ClinicalTrials.gov/show/NCT01022216.
62 Berriman S, Moquin K. Efficacy of Quantum NPWT With Simultaneous Irrigation on Reduction of Wound Volume in Stage III/IV Pressure Ulcers. ClinicalTrials.gov [internet]. 2012. cited 2014 March 18. Available from: http://ClinicalTrials.gov/show/NCT01734109.
63 Integra LifeSciences Corporation. Retrospective Study Evaluating Outcomes for Integra® Skin Sheet Products in Lower Extremity Complex Wounds. ClinicalTrials.gov [Internet]. 2013. cited 2014 March 18. Available from: http://ClinicalTrials.gov/show/NCT01947387.
64 Schubart P. Clinical Evaluation of the Combined Use of Apligraf® and the SNaP® Pressure Wound Therapy System. ClinicalTrials.gov [Internet]. 2013. cited 2014 March 18. Available from: http://ClinicalTrials.gov/show/NCT01623882.
65 Moffatt C. Clinical and Health Economic Study of PICO in a Community Care Setting. ClinicalTrials.gov [Internet]. 2012. cited 2014 March 18. Available from: http://ClinicalTrials.gov/show/NCT01683344.
66 Vuerstaek J. A Randomised Controlled Trial Comparing Vacuum Assisted Closure (V.A.C.®) With Modern Wound Dressings. ClinicalTrials.gov [Internet]. 2005. cited 2014 March 18. Available from: http://ClinicalTrials.gov/show/NCT00243620.
67 Attinger C. ActiV.A.C.+ Compression Therapy Versus Compression Therapy Alone for the Treatment of Chronic Venous Ulcerations. ClinicalTrials.gov [Internet]. 2013. cited 2014 March 18. Available from: http://ClinicalTrials.gov/show/NCT01528293.
68 Margolis DJ, Kantor J, Santanna J, Strom BL, Berlin JA. Risk factors for delayed healing of neuropathic diabetic foot ulcers: a pooled analysis. Arch Dermatol. Dec. 2000;136(12):1531-1535. [pmid: 11115166].
69 Blume PA, Walters J, Payne W, Ayala J, Lantis J. Comparison of negative pressure wound therapy using vacuum-assisted closure with advanced moist wound therapy in the treatment of diabetic foot ulcers: a multicenter randomized controlled trial. Diabetes Care. Apr. 2008;31(4):631-636. [pmid: 18162494].
70 Frykberg RG, Williams DV. Negative-pressure wound therapy and diabetic foot amputations: a retrospective study of payer claims data. J Am Podiatr Med Assoc. Sep-Oct. 2007;97(5):351-359. [pmid: 17901338].
71 Argenta LC, Morykwas MJ. Vacuum-assisted closure: a new method for wound control and treatment: clinical experience. Ann Plast Surg. Jun. 1997;38(6):563-576. discussion 77. [pmid: 9188971].
72 Vuerstaek JD, Vainas T, Wuite J, Nelemans P, Neumann MH, Veraart JC. State-of-the-art treatment of chronic leg ulcers: A randomized controlled trial comparing vacuum-assisted closure (V.A.C.) with modern wound dressings. J Vasc Surg. Nov. 2006;44(5):1029-1037. discussion 38. [pmid: 17000077].
73 Maderal AD, Vivas AC, Eaglstein WH, Kirsner RS. The FDA and designing clinical trials for chronic cutaneous ulcers. Seminars in cell & developmental biology. Dec. 2012;23(9):993-999. [pmid: 23063664].
74 Food and Drug Administration. Guidance for Industry: Chronic Cutaneous Ulcer and Burn Wounds - Developing Products for Treatment. 2006. cited 2014 August 13. Available from: www.fda.gov/downloads/Drugs/GuidanceComplianceRegulatoryInformation/Guidances/ucm071324.pdf.