# How to Use Multiple Sequence Aligners in Genome Workbench

We added three MSA programs to GBench: Kalign, MAFFT, and Clustal Omega, to complement the two existing programs, MUSCLE and ClustalW. This video shows you how to import sequences for alignment, run the MSA program, and display the results in GBench's multiple alignment view.

If you use multiple sequence alignment in your analyses, we are pleased to announce the addition of three third party multiple sequence alignment programs to our Genome Workbench application. With the June 2017 release of GBench version 2.12.0, we added Kalign, MAFFT, and Clustal Omega to the two existing multiple sequence alignment (MSA) tools, MUSCLE and ClustalW. This video demonstrates the use of KAlign on a set of nucleotide sequences. Combined with GBench's multiple alignment view.0.er, which projects sequence features onto the alignment, using GBench's MSA tools is a good way to visually compare sequence properties. I'm going to go to GBench's on-line manual for Multiple Sequence Aligners to show you the complete list of MSA programs available, along with the locations for downloading the programs. You need the MSA program on your local machine for GBench to access it. And if you want to use Kalign on Windows, please use the source code or binaries that we provide on our ftp site. (ftp.ncbi.nlm.nih.gov/toolbox/gbench/kalign) Also notice the example fasta files. I'll be using this example set of bacterial 16S sequences in my demo on a Mac. Switching over to the GBench application, the first step is to import that FASTA file, so I'll use this Open icon, make sure that File Import is selected, then click on Add files. As long as the path here is correct, click Next, you can accept the defaults, click Next again, and on this menu I'll check the box to create a folder for the data, let's call that 16S_demo, and click Finish. You can follow the status of the import in the Task View. We now see the sequence records, so I'll select them all, using the Shift key, then right-click and choose Run tool... And here we see the five MSA tools, now in there own section of the tool menu. I'll choose Kalign. And with all of those sequences selected, check or set the path to the program, then click Finish. I'll double-click on the result, choose the "Multiple Alignment view", and then I can click and drag to change view sizes, or simply minimize the Project View. Now we're looking at the full sequence lengths in the default display, which shows frequency-based differences. You can change the settings by right-clicking anywhere in the graph and using the Coloring menu to select a different coloring method, or the method's properties. You could also export the alignment in FASTA format or in a variety of other formats. That concludes this brief demonstration. In the Multiple Sequence Aligners manual where I started, you can download GBench project files that contain examples of all five MSA's and also find links to help documentation on the coloring methods. And please send us your questions and feedback, by using the Help - Send feedback menu found within Genome Workbench.

This video is also available on YouTube. [image]https://youtu.be/uYSvTsrdufQ