# My NCBI Track Collections: Introduction

Introduction to NCBI genome browser track collections, a way to store and share custom sets of tracks.

This video introduces My NCBI Track Collections, a way to store, re-use and share a set of tracks that you configure within one of NCBI’s genome browsers. Track collections are stored in your My NCBI account, just like other collections, such as PubMed records. If you are not familiar with our browsers, which include the Variation Viewer, the 1000 Genomes browser, and the NCBI Sequence Viewer graphical displays, such as those embedded on Gene, dbSNP, Clone DB, and other record pages, we provide active links near the end of this video to those browser tutorials. I’ll to start in the NCBI 1000 Genomes browser, which you can get to from a link on this NCBI Variation page. The "Tracks" button, formerly known as the "Configure" button, and found at the top right of the graphical view, is used to customize the display. For example, I'll go to Tracks/Configure tracks to remove a few tracks, re-order others and add a new one. After clicking Configure, the display updates to my new track configuration. If I want to save this new set of tracks, I must be logged in to My NCBI or first register for a free account. You can login via the "Tracks" menu or the link at the top right of any NCBI page. I’ll use the Tracks menu to log in. Now I can see my existing track collections, notice that mousing over a collection displays a list of it’s tracks, and I can save the current set as a new collection. Clicking on a track collection loads the corresponding tracks into the display. Track collections can be loaded into other NCBI genome browsers or sequence viewer displays. Be aware, though, that within a given resource, the Track Collections menu will list only the track collections relevant to the displayed sequence or assembly. For example, my 1000 Genomes track collections were created for the GRCh37 assembly, the only one currently available in the 1000 Genomes browser. So if I go to the Variation Viewer, by default it displays GRCh38, and my 1000 Genomes track collections are absent. However, when I change to the GRCh37 assembly, they show up. To edit the content of a Collection, click the "Manage collections" menu option, which takes you into the My NCBI interface. Here, track collections are Type "TMS", for Track Management System. You can delete an entire collection by selecting it and clicking Delete. To modify the content of a collection, click the "edit" link. You can then select individual tracks to delete from the collection, or perform other editing operations. To share a collection with someone else, you can click here, make it public, or click the gear icon in the My NCBI interface. In both cases you will get a public URL to share. That's all for this quick demo. For more information on track sets, click the FAQ link at the bottom of the Tracks menu or contact the NCBI Help Desk.

This video is also available on YouTube. [image]https://youtu.be/76gLdUT712c