# Sequence Viewer: Display Translation Discrepancies

This is a brief introduction to a new set of sequence viewer renderings that better display discrepancies between genomic sequence and annotated features. These discrepancies can occur because RefSeq gene models based on the current genomic sequence can differ from RefSeq transcripts and corresponding proteins that come from our continuous curation efforts.

Recent enhancements to NCBI's Sequence Viewer, can be found in the Release Notes and include better ways to display discrepancies between genomic sequence and annotated features. These discrepancies can occur because RefSeq gene models based on the current genomic sequence can differ from RefSeq transcripts and corresponding proteins that come from our continuous curation efforts. Let's look at a few examples of the new rendering for such discrepancies. In the first example, I'm zoomed in on a portion of chromosome 1 from Zea mays cultivar B73, and we've added markers for a codon mismatch - there are 4 codons here with mismatches - a coding sequence (or CDS) deletion, and a CDS insertion, all in an exon of a gene. This view also shows the RefSeq Alignments track with mismatches in red. The new renderings in this case are: - codons below the protein bar. If red, there is a mismatch in one of the three bases; red codons could represent either synonymous or non-synonymous amino acid changes. - amino acid single-letter codes on the protein (red) bar. These are present only when the amino acid is changed. - transcript bases on the RNA (purple) bar. These display only when the transcript sequence differs from the genomic. - dashes on the RNA and protein bars. These represent deletions relative to the genomic sequence. - hourglass-like triangles on the RNA and protein bars. These represent insertions relative to the genomic sequence. Now lets look at the special case of ribosomal, or translational, slippage. In this example, we are looking at a region of Sus scrofa chromosome 9 and we've added a marker called slippage. Notice the addition of an A in the first transcript compared to the second one. As a result, the codons - beginning with AAA (for lysine) - are shifted to the left relative to the those in the second transcript; see the position of AAC (for asparigine). A second example comes from chromosome 2 of the same assembly. Here you see insertion of a one base pair gap, which is necessary to avoid the TGA stop codon. Like the other discrepancies, this slippage is displayed because we take information from feature notes in the RefSeq records. In this case the note said that protein translation is dependent on +1 polyamine-induced ribosomal frameshift. That concludes this tutorial. We encourage your feedback, so please use the help menu next to Tracks to let us know how we can make Sequence Viewer better. And find help, including a legend for all Sequence Viewer tracks, from this help link.

This video is also available on YouTube. [image]https://youtu.be/x5eZfJtkME4