# SciENcv: Science Experts Network Curriculum Vitae

This video focuses on special features in SciENcv that help users create, share, and maintain NIH Biosketch profiles for federal grant applications. However, anyone with a My NCBI account may use SciENcv. http://www.ncbi.nlm.nih.gov/sciencv/

SciENcv is a free profile service that is part of My NCBI, offered by the National Institutes of Health. This video focuses on special features in SciENcv that help users quickly create, share, and maintain NIH Biosketch profiles for federal grant applications. However, anyone with a My NCBI account may use SciENcv. I'll click this big, green button and go to my SciENcv main page. This mini profile is very handy because you can edit your name to appear exactly as you want in other resources that use these data. I'll go to edit and show you an example. Using the Name displayed as field, I'll add a middle initial and change my credentials. Back on the main page, if you have more than one profile, you will see a list here. And use this link to generate a new profile. SciENcv offers 3 options when creating a new biosketch profile. You can create one from scratch starting with a blank page. You can use an external source to populate sections of the biosketch. This currently works with eRA Commons profile information and will be extended to other profiling systems in the future. Or you can duplicate an existing biosketch and edit from there. Be aware that after external information is brought into a profile, it is editable by the user and will not automatically update from the external source. Back on the main page, again, I want to show some editing options within an existing profile. You can choose to share your profile here, and the sections are independently editable. For example, I may want to hide an Education/Training entry in this profile, by unchecking it. Or edit an entry; mouse over the entry and Delete and edit options become available. The publications section of SciENcv is linked to your My Bibliography collection. In My Bib a you can add citations from PubMed, create manual citations for items not found in PubMed, and fulfill NIH grant reporting requirements. If your eRA Commons account is linked to My NCBI, awarded grants appear automatically in this Research Support section. You also have the option to create manual grant entries for awards from other funding agencies. Additional award feeds for these agencies will be added to SciENcv in the future. Back at the top of this page, you see that biosketches can be downloaded in PDF, Word and XML formats. The PDF format can be used in grant application submissions that go through grants.gov. Finally, just a reminder that anyone with a My NCBI account can create biosketch profiles. In addition, you can assign delegates to manage your profiles. Follow the username link back to your My NCBI settings and you can to assign delegates independently for SciENcv and My Bibliography. We welcome feedback on SciENcv; please send email to info@ncbi.nlm.nih.gov. Additional information, plus links to help documentation, is available on the SciENcv home page at the address shown. http://www.ncbi.nlm.nih.gov/sciencv/

This video is also available on YouTube. [image]http://youtu.be/PRWy-3GXhtU