# PubMed: The Filters Sidebar

This tutorial introduces and explains how to use the PubMed filters sidebar. These filters replace the PubMed Limits page.

This short video demonstrates how to use the PubMed filter sidebar. These filters replace the Limits page, bringing the same functionality as Limits directly to your search results page. My example search uses the query, pollen allergy. In the sidebar you see a default set of filter categories. To change this list, click "Choose additional filters", select the desired categories, and then click Apply. Note that 'Text availability' and 'Publication dates' cannot be removed. To narrow my search results, I'll filter for articles published in the last 5 years that are also Article type, Clinical Trial. A "Filters activated" message appears. Just as with Limits, once a filter is active, it remains in effect for subsequent searches until it is cleared. You can clear active filters in several ways. Use the "Clear all" links, the 'clear' link for all filters within a category, or click an active filter. Within a category, applying additional filters actually expands your search rather than narrows it. This is because the additional filter is included as an OR term. For example, adding Review expands my results today from 404 to 787. If you wanted to narrow your search with Review, use Search Details to change the OR to an AND. Now I get a single abstract today. Also, be aware that only valid filter options for your particular result set are available. For example, we see Practice Guideline when "OR Review" is active, but it disappears when Review is cleared, because none of the citations in this smaller set were tagged with type, Practice Guideline. Finally, you may have noticed that the default Review and 'Free full text' filters have been moved to the sidebar. The My NCBI 'Manage Filters' function will eventually be incorporated into the filters sidebar. Your feedback and questions are welcome. Please use the 'Support Center' link near the bottom of the page.

This video is also available on YouTube. [image]http://youtu.be/696R9GbOyvA