# PheGenI: The Phenotype-Genotype Integrator

A January 2013 update to the PheGenI (http://www.ncbi.nlm.nih.gov/gap/PheGenI) tool, part of dbGaP. Changes include: autocomplete search for Traits; example searches; source choice; and enhanced Genome View.

This video covers the basics of using PheGenI (fee-GEE-nee), the Phenotype-Genotype Integrator. A good overview of this resource is provided at www.genome.gov/27543987 I'll start on the PheGenI home page. Your first choice is whether to search by phenotype, genotype or a combination of the two. A few example searches are provided by clicking the "Examples" button. And be sure to click on the help icons. They provide useful tips about using the autocomplete and Browse functions to input traits, and the different ways to represent chromosomal ranges. I'm interested in asthma, so I'll start typing asthma under Traits, then select the term. I also want data on autoimmune diseases, so I'll add that. And I could set a P-value cutoff, or select a source, but I'll just click Search. Search Results acts as a table of contents for this page, where the five section names are links within the page. Let's look at the Association Results, which offers the most comprehensive table. The default sorting is by P-value, but all of the columns, except rs numbers, are sortable by clicking the column name. P-values are linked to the dbGaP genome browser. From the Association Results, I can get back to my Search Results by clicking this arrowhead. Let's take a look at the Genome View, which gives me an ideogram rendering of gene and SNP locations. You can mouse over an arrowhead to display information, and click on the arrowhead to open a graphic display of that genomic region; it opens just below the ideogram. This is a fully functional display, so you can scroll, zoom, change tracks, etc. Videos about this sequence viewer are available on the NCBINLM YouTube channel. Finally, let's look at the expression QTL (eQTL) data. You can learn more about these data at the gtex URL shown, http://www.ncbi.nlm.nih.gov/gtex/ but basically, this is an association of genetic variants with gene expression values. In this example, one of the expression probes links to a box plot, which displays gene expression levels for the three genotypes represented by this SNP in three populations. That's a brief tour of PheGenI. You can email questions to, info@ncbi.nlm.nih.gov.

This video is also available on YouTube. [image]http://www.youtube.com/watch?v=v_yEy--HcKc