# My NCBI: My Bibliography

A tutorial demonstrating how to use the My Bibliography component of My NCBI.

This video is also available on YouTube. [image]http://youtu.be/9gApmLHdCSM