# The New MSA Viewer

This video demonstrates the basic functions of a new multiple sequence alignment viewer for both amino acid and nucleotide sequences. The application can be embedded into web pages and has a large number of options. For documentation, see: www.ncbi.nlm.nih.gov//tools/msaviewer/

We are introducing a new web application, MSA Viewer, that provides an interactive display of multiple sequence alignments for both amino acid and nucleotide sequences. This is the Viewer’s documentation page. The URL is the base NCBI URL, followed by forward slash tools forward slash msaviewer. Here you can learn about embedding the viewer in your web pages, and explore the viewer's capabilities on these demo pages. I'm going to move over to an NCBI page that is using the API; it's this link, Multiple Sequence Alignment Viewer application. Here you find several examples of both amino acid and nucleotide alignments. With this Upload function, the Viewer accepts alignments from many programs, such as MUSCLE or one of the Clustal programs, as well BLAST results in the form of a BLAST Request ID, or RID, number. I'm going to demonstrate a MUSCLE alignment by following the link of the same name, then I'll point out the main controls of the viewer. This slider allows you to zoom, or you can zoom directly to the sequence by clicking the ATG symbol. You can click and drag the image to pan or use the left and right arrows. If you want information on a particular column, simply mouse over a position, and you get a pop-up showing statistics for that position, and you can click on this thumb tack image to keep the pop-up open. A left-click, or right-click if using a Mac, on a sequence row offers several functions, including the ability to set that sequence as the master. I'll do that, and now you see the sequence at the top of the alignment. Clicking a plus symbol for a sequence expands the view to show features, such as domains, binding sites, active sites, and so on. This menu also has several options for changing the coloring scheme. Notice that the Tools menu also allows you to set the coloration method. Those are the basics of the MSA Viewer. This help menu next to Tools offers the ability to create a link to the current view that you could send to a colleague, and a Feedback form to make comments; we’d really like to hear from you. And this question mark in the upper right of the page opens the documentation page where we started.

This video is also available on YouTube. [image]https://youtu.be/NZ1vsIp0j_8