# Highlight Sequence Features

This video describes a function on Entrez Nucleotide and Protein pages that highlights the sequence associated with features in the record.

The newest member of the “Analyze this sequence” family is Highlight Sequence Features. If the Nucleotide or Protein record that you are viewing contains a CDS, or coding sequence, feature, then clicking this link takes you to the sequence representing that CDS. In this case we’re looking at the highlighted CDS for the androgen receptor gene. And if you want the FASTA formatted sequence for the highlighted regioin, click on FASTA. Some records don’t have a CDS feature. In that case, the Highlight Sequence Feature link takes you to the first feature in the record. If you are wondering what exactly is a feature, I’ll first close the highlight function by clicking the “X”, then scroll back up the record to the section we call the Feature table. These are a defined set of annotations that describe regions of biological significance in the sequence. You can read more about these annotations in the “Features Format” section of the GenBank release notes, which you can find at this URL: ftp://ftp.ncbi.nih.gov/genbank/gbrel.txt Notice that these feature names are also links. I’ll click on misc_feature. This one is an upstream in-frame stop codon. If you look at the footer of this page, you’ll find a pull-down menu that allows you to select any of the feature types in this record, and then scroll through those types. For example, the second misc_feature is a potential phosphorylation site for the CDK9 phosphoserine kinase. For more detail about the Highlight Sequence Feature, click the Help link. And if you have questions, send those to: info@ncbi.nlm.nih.gov

This video is also available on YouTube. [image]http://youtu.be/9jzL5S9bkww