# Migrate Clinical Test Data from GeneTests to GTR

Step-by-step instructions for migrating clinical test data from GeneTests (http://www.ncbi.nlm.nih.gov/sites/GeneTests/) to GTR (http://www.ncbi.nlm.nih.gov/gtr/). Also see the companion video, Migrate Laboratory Data from GeneTests to GTR.

This is a companion video to 'Migrate Laboratory Data from GeneTests to GTR.' You need to migrate your lab data before migrating tests. If you want help with that, click the note here, or the one at the end of this video, to view the lab migration video. Help documents on both migration tasks are available at the link shown: www.ncbi.nlm.nih.gov/gtr/docs/submit I'll begin on my mock GTR Submission homepage, having already signed in via My NCBI, and I'll follow the link to "Migrate data from GeneTests." After logging in to GeneTests, I'll click the link 'Migrate Clinical Test Data.' We strongly recommend that you migrate only one test at a time. If you have a large number of tests to migrate, see the documentation on Bulk test submission. I'm going to migrate this test, Noonan Syndrome, so I'll check that box and click the button Migrate Selected Tests. If you have a long list of tests, you may need to scroll down the page to see that button. I'll now click OK in the popup window and follow the link to View/Edit Test Submission. I will now progress through these seven pages, filling in at least the Required fields, those with asterisks, clicking the "Save & Continue" button at the bottom of each reviewed page, and, finally, clicking the "Submit" button on the Overview page. On this Basics page I'll add the Laboratory test name 'Noonan Syndrome PTPN11 Sequencing with Reflex to SOS1 known mutations.' My test has two genes, PTPN11 and SOS1, which are the cause of two specific types of Noonan syndrome — I'll show you how that works when I get to the Indication and Methodology pages. On this page, I'll scroll down and select two test purposes, diagnosis and risk assessment. I'm going to add recommended information on the test's target population, but, first notice the help text that pops up when I hover the mouse over the '?' or help icon. Since this is an LDT, or laboratory developed test, I'll select that and leave the FDA related information as 'FDA exercises enforcement discretion.' That's all I will enter on this page, so I'll click Save & Continue. The Ordering page has no required fields, but here you can provide test order codes, URLs to your website, information on who can order the test, specimen sources, and you can select the staff person you want to display as the contact for this test. Enter the data you feel is useful to someone ordering your test, then scroll down and click Save & Continue. Noonan's syndrome was the condition name provided to GeneTests, so it was migrated here. I'm testing for specific subtypes 1 and 4 of Noonan syndrome based on my gene targets PTPN11 and SOS1. To make my test more discoverable, I'm going to attach my test to any and all relevant conditions that GTR users might search for. So, I'll click 'Add indication/condition name', type Noonan syndrome in the condition/phenotype box, click on the autocomplete choice, scroll down and click Save. I'll repeat these steps for Noonan syndrome 4Ébut on the way down to Save, I'll point out that you can add synonyms, provide a preferred acronym, submit information on prevalence, and send a private comment to the GTR staff if, for example, you are having difficulty finding a condition name in the autocomplete list. To summarize, I'm testing for three conditions — the parent term and two subtypes — and this will help GTR users locate my test. I'll cick Continue, which takes me to the Methodology page. The Major method category (Molecular genetics) and the Method category (sequence analysis of the entire coding region) have migrated over. I need to provide the third level of information, Primary Test Methodology, which in this case is 'Bi-directional Sanger sequence analysis' and corresponds to my doing complete sequence analysis on the PTPN11 gene. Since I also do reflex testing to known SOS1 gene mutations, I'll need to add that as a second methodology. You can add another method here. I'll complete the three methodology fields as above, except that the Method category is 'targeted mutation analysis.' At the bottom of the page, I'll add the test targets, in this case genes I'm testing for. Then I will connect the gene targets to the relevant conditions and add information on the SOS1 variants in my test. I'll start by clicking 'Add Test Target.' The PTPN11 gene goes with the parent term Noonan's syndrome and the specific condition NS1, so I'll check that, select 'gene' in the 'Target is identified by' field, and type in and select the PTPN11 gene. I don't test for specific variants of this target, so I'll click Save Target. I'll next add the SOS1 gene, associating it with the NS4 type. Since I test for specific variants, I'll select Variants, start typing NM, and select the first variant. I'm only going to demonstrate adding one variant, but you can add all variants in your test by using the 'Add another variant' menu to enter them one at a time. Some of these variants are disease-causing, so I'll select 'pathogenic' under 'Clinical significance of variant'. This helps NCBI improve access to information about medically important variation through a companion resource called, ClinVar. I'm finished with Methodology, so I'll click Save Target, then Save & Continue. In the Interpretation page you can upload sample reports and describe how your laboratory interprets and reports variants of unknown significance. I will just move on to Performance characteristics. The test performance location is preselected on migrated tests for the entire test performed in-house, but please read this and make sure it is accurate. The analytical validity field needs to be completed using a quantitative statement that is specific for each test; I'll paste in this statement. The bidirectional sequencing of the entire PTPN11 coding region and intron-exon boundaries has analytical sensitivity and specificity of 99 percent. The target mutation analysis of SOS1 has analytical sensitivity and specificity of >99 percent. The quality assurance section is not required, but is a good way for you to demonstrate the standards used by your laboratory. The Clinical validity statement is recommended; here I'll paste in this statement Sequence analysis of all exons of PTPN11 detects missense mutations in about 50% of individuals tested and mutation scanning detects missense mutations in 10-13% and I'll reference GeneReviews by entering the PubMed ID. PMID:20301303 I'll complete the recommended field, Clinical Utility, by selecting a category from the drop down list, 'Guidance for management' in this case, which is well supported by this guideline, PMID:20876176.Ê That's all for Performance Characteristics, so I'll click Save & Continue. I now can review information on all of the pages and use this link to see how my test will display in GTR. After clicking Submit, my test will appear on the GTR public site within 24-48 hours and I can double check the display there. Clicking Submit takes me back to the GTR Submission homepage. To migrate another test I would start, as at the beginning of this video, with "Migrate data from GeneTests" and then click "Migrate Clinical Test Data." You can click on the note to go to the video on migrating laboratory data. And please email questions and comments to the address shown: tkt-tryhd@ncbi.nlm.nih.gov

This video is also available on YouTube. [image]http://youtu.be/Gb1eWLb1Wuw