# Migrate Laboratory Data from GeneTests to GTR

Step-by-step instructions for migrating clinical test data from GeneTests (http://www.ncbi.nlm.nih.gov/sites/GeneTests/) to GTR (http://www.ncbi.nlm.nih.gov/gtr/). Also see the companion video, Migrate Clinical Test Data from GeneTests to GTR.

This video shows you how to migrate laboratory data from GeneTests to GTR. You should think of migrating data as a two step process, laboratory information first and tests second. For a video on test migration, follow the link at the end of this video. Help documents on both steps are available at the link shown: www.ncbi.nlm.nih.gov/gtr/docs/submit The tabs in these help documents correspond to the tabs you'll be working on, so you may want to keep a separate window open to the corresponding help page. I'll start on the GTR Submission homepage, having already signed in via My NCBI and having accepted the Code of Conduct after the first successful log in. I'll begin by following the link to "Migrate data from GeneTests". After logging in to GeneTests... you may see more than one lab listed. I've got only one and I'll follow the link to "Migrate Lab Data" At this point, I’ve copied my data from GeneTests to GTR, but I'm not finished. I'll first follow the link to "View/Edit Lab submission." Now I have three general tasks; I need to: 1) review each of these pages and fill in any gaps for “minimal” fields, which are marked by asterisks, 2) click the "Save & Continue" or "Continue" button at the bottom of each reviewed page, and, finally, 3) click the "Submit it" button on the Overview page. For example, on this "Lab information" page I need to complete the phone number and email address fields, since these data were not originally provided to GeneTests, then I'll scroll down and click "Save & Continue." I'll make no changes on the Personnel page, but as the text indicates, we recommend making this personnel list as complete as possible at this point. If I later want to add someone as a test-specific contact, and they are not entered here, I have to come back to this page. After clicking Continue I now can review and edit Licensure information. These blue question mark icons offer help tips when I hover my mouse over the icon. I'll just click Save & Continue... and on this next page, Default parameters, if I am planning to enter any of my tests as new tests rather than migrating them, I can save considerable time by entering information common to many tests. I'll scroll down and click Save & Continue... I now can review information from all of the tabs, and use this link to see how this lab will display in GTR. The preview opens in a new window, and points out that I have one more task back on the Overview page, to click the "Submit it" button. After I click the button, my data will be viewable on the GTR public site within 24-48 hours, and I can double check it then. This takes me back to the GTR Submission homepage. The lab submission status for Mendel Laboratory has been updated and I'm ready to move on to migrating tests by following the link to "Migrate data from GeneTests." I now see a new link, "Migrate Clinical Test Data," which is where I'll start in the next video called, Migrate Clinical Test Data from GeneTests to GTR. You can click on the note to go to that video now.

This video is also available on YouTube. [image]http://youtu.be/erua-G5j5hw