# GTR: Homepage and Basic Search Functions

A tutorial describing the homepage for the Genetic Testing Registry (http://www.ncbi.nlm.nih.gov/gtr/) at NCBI and demonsrtating basic search functions.

This video provides an overview of the home page for the NIH's Genetic Testing Registry (GTR), and also demonstrates some handy search tips. A separate video specifically addresses how to quickly find tests in GTR. Starting on the homepage, I’ll first point out that no matter where you are on the GTR website, clicking the logo brings you back to this page. Your primary activity on this page is to search for information. By default, entering a search term here will search all of GTR, but you can restrict your searches by these categories. Selecting a tab displays suggested types of search terms for that category, and often provides a faster path to your results. For those of you interested in pharmacogenetic terms, try the Conditions/Phenotypes tab. As GTR grows and contains more drug response data, [type warf] searching for such terms under Conditions/Phenotypes could save you time. Here’s another example under Conditions/Phenotypes. I’ll type the word, learning, and, ignoring the choice provided, I’ll click the Search button. This full search provides a short differential of conditions containing the term ‘learning’ somewhere in the descriptions. Notice that, while there are many more than 19 genetic conditions with the word ‘learning’, GTR shows by default those conditions with available tests. You can select other features here, such as OMIM records or GeneReviews, or the full set of 34. I want to point out that you don't have to search from the hompage. This drop-down menu and search box have the same search range as the homepage, except for GeneReviews, which is part of NCBI’s Books database. To demonstrate a GeneReviews search, I’ll go back to the homepage and search for reviews about the condition, Ehlers-Danlos. Typing Ehlers retrieves 20 records, today, that have ‘Ehlers’ in the title or text of the record. You can also search GeneReviews with other terms, such as author names. I’ll now go back and focus on features of the home page. The left side of the page has information specific to GTR, such as help documentation, background on the GTR, how to submit tests, and the Code of Conduct. On the right you’ll find Clinical Resources such as OMIM, several ways to locate a genetics professional, consumer resources, and a few of NCBI’s molecular resources. I’ll end with few words about how you can provide feedback to the GTR. We’ve developed a structured feedback form that you can complete very quickly. Your input will help us to make the GTR a true community effort. Thank you.

This video is also available on YouTube. [image]http://youtu.be/VmDo1DjOyBY