# GTR: Advanced Search Function

The Advanced search function is designed to quickly help find tests, including panels

GTR: Advanced Search Function This video shows you how to use the GTR's customizable Advanced search function to quickly find the tests you want. Let's say a woman comes to you for pre-conception counseling. She's concerned about her paternal family history of unspecified cardiomyopathies and has a paraffin block for analyzing her father's DNA. You want a lab that can perform both a cardiomyopathy panel and prenatal testing. I'll begin on the GTR home page and click the link, Advanced search for tests. You see three default categories of criteria on the left, but those are just starting points. You can add more rows of criteria using the plus icon here on the right. Let's take a quick look at the possible criteria. You have 14 in all, broken down by Condition, Gene, Lab, Test and Method. Okay, let's start the search for a cardiomyopathy panel. For Condition name I'll type cardiomyopathy in the text box. As I do that, I see a list of suggestions, but since I don't know the type of cardiomyopathy I want, I'll click outside the text box rather than select from the menu. This searches all conditions with the name cardiomyopathy, and adds a term in the built search box below. I want a multi-gene panel, so I'll change the next category to Number of genes, and I now get the option to specify a range. I'll put 5 in the greater than box, and leave the upper limit empty. Next I'll specify that my sample is embedded in wax by changing the third criterion to Specimen type, and selecting Paraffin block. My last step is to find a lab that can perform the prenatal analysis. I'll use the fourth row that I added earlier, choose Services, then select Custom Prenatal Testing in the menu. I'm happy with this query, but before clicking Search, I want to point out that each term here is connected by AND in all caps. This means that *all* of these criteria must be met. You can click this Edit link to modify the query at this point, but I'll click Search and see what I get. I see two cardiomyopathy panels, one targeting 70 genes, and another with 7 targets, so that's very promising. Of course, I can get more information by clicking on a Test name. One final note about editing the search. If you feel like your search was too restrictive, don't click the browser's back button to make edits. Just use the search box near the top of the page. In this case, I might want to lower the number of genes or remove that term all together. Another option is to change one of the ANDs to an OR. To see more tips, use this Help link on the Advanced search page. And as always, we welcome your feedback and questions, so please make use of this contact us link on the GTR home page.

This video is also available on YouTube. [image]https://youtu.be/8VVfz6wjTfo