# GTR: Locate a Test in Under Three Minutes

A tutorial demonstating search strategies for locating genetic tests and laboratories in the Genetic Testing Registry (http://www.ncbi.nlm.nih.gov/gtr/) at NCBI.

We designed the Genetic Testing Regsitry, or GTR, to make finding a genetic test as easy and efficient as possible. Here, you will see different ways to locate a specific genetic test in under 3 minutes. The fastest way is to search with a test name. From the GTR homepage, I’ll click on the Tests tab, enter the name, Otochip, and click Search Tests; your keyboard’s Enter or Return key also initiates the search. This takes me to a list of tests, with the exact match on top; the other tests refer to OtoChip somewhere in their descriptions. I’ll click on the link, OtoChip Test, and we’re done! That was well under 3 minutes, but, what if you don’t recall the exact test name? Let’s look at some other search strategies. I’ll go back to the GTR homepage. A common scenario might involve you and a patient who is at risk for some disorder, let’s say, M-E-N-2. Using the conditions/phenotype tab, I can search by typing the acronym, MEN2, or I could spell out multiple endocrine neoplasia, and the autocomplete function helps me out. I’ll select the first option, MEN2, and I am immediately taken to the disease-specific page for multiple endocrine neoplasia type 2. There is a lot of useful information here, but I’ll just scroll down to the Available Tests section. Here, you’ll find a link to ‘See all available tests.’ And under that a list of method categories. Let’s say I only want tests performed by deletion analysis. I’ll click the deletion/duplication analysis link to retrieve those 9 tests. I could limit this set even further by using the filters on the left, or, use the Compare labs function to help me choose among the providers. Now, for each lab I can see the methodologies they provide for MEN2, and whether or not they also provide custom or family-specific carrier or prenatal testing. I’ll now go back to the GTR hompage and try another approach. Let’s say I have a specific gene in mind, and I know the gene symbol is L1CAM. I’ll select the Genes tab, type in L1cam, and click Search Genes. I can click the link for L1CAM, here, to learn more about the gene itself, but I want test information, so I’ll click on Tests. I now have the familiar page of tests, that I can filter or compare as I showed for the MEN2 results. I next want to search by laboratory. Rather than going back to the homepage, I’ll start a new search right here by changing to Labs in the drop-down menu, and let’s say I want a lab at Harvard, so I’ll type Harvard in the search box, and select this third choice. Here we have a long list of tests associated with a particular condition or phenotype. You can narrow the conditions list by typing in this box. I’ll look for alagille, and now I can go to that test’s page. Let’s look at one more example, searching for a test using ALL GTR. I’ll enter cystic fibrosis and click Search. The search results are grouped by the four major categories, with links both along the top, and the left side of the page. As you scroll through the categories, you’ll see that only 3 results per category, but we have links to the complete set. That’s a quick tour of search strategies. Thank you for your interest in the Genetic Testing Registry.

This video is also available on YouTube. [image]http://youtu.be/HeS4Jvdy194