# Genome Workbench: Import BAMs and Export Alignments

Learn how to import BAM files, create a BAM index file, and export selected alignments using NCBI's Genome Workbench.

Genome Workbench: Import BAMs and Export Selected Alignments This video shows you how to import BAM files and export alignments while using NCBI's stand alone program, Genome Workbench. The basic steps in this video are in an on-line tutorial called, Working with BAM Files, which I'll go to now from the Genome Workbench home page. My example includes how to create a BAM index file, so I'm going to use an unsorted BAM file with no index and no coverage graph. And that means that I'll also need a local copy of samtools, which I can get from this sourceforge link. Okay, I've opened my genome workbench application, which I happen to be running on Mac OS X 10.9. To load my BAM file, I could either use the File-open icon, or the keystroke, command-O; I'll do the latter. Make sure that BAM/CSRA is selected, then click the Add button. I'm going to open this BAM file, verify that I have the file I want, then click on Next. And, as I mentioned, this BAM file has not been indexed, so I now want to point to my local copy of samtools, and then click Next. I want to map these alignments to an NCBI assembly, so I'll show you how to choose one by clicking on Find Assembly. We have a long list here. And since my BAM file aligns well to the NCBI36, or hg18, assembly, I'll choose that. I want to point out, though, that my BAM file uses UCSC-style sequence identifiers, but this Find Assembly function allows Genome Workbench to convert those to the NCBI assembly identifiers. I'll go ahead and click Next, and create a new project by clicking Finish. You get status information in the task view panel, so I can see that the file is loading, sorting, and so on. And now I have the project in the Project Tree View. I'll expand this panel a bit to see the full file names, and then by double-clicking on the data file name, I can specify that I want a Graphical Sequence View of the alignments. I can then choose one or more of the NCBI chromosome records as the top-level sequence to display. And since I chose an older assembly, I'm more likely to see a warning like this, telling me that a newer version of this chromosome record is available. I'll just click Okay. And note that if I had selected multiple chromosome records, each would have it's own tab in this graphical view. The Alignments track is the lowest track in my display. And you have multiple ways to zoom in to see the actual alignments, or to get a region of interest. I'm going to right-click to get this menu, and specify a sequence range to go to. I'll move along this range a bit. If I'm sure that this is the region that I want to export, I could do that now by selecting the region, right-clicking, and selecting export. But, let's say I first want to verify that these are the alignments I want. As I mentioned, you have several ways to zoom in. I'll end up at this sequence level, where the red-shaded bases indicate variation from the NC_ record up top. I'll now select this region and choose the export menu. Here I can input a file name and choose the location to save the file using this button in the lower right. Then on the next menu I select the fields I want in my exported file, and click Finish. As you can see, this file is easily opened in a spreadsheet application for further use. That ends this demonstration. Please see our other tutorials and videos, and the FAQ page has email addresses to send comments, questions and bug reports.

This video is also available on YouTube. [image]https://youtu.be/mBGPJQ_p9W8