# Genome Workbench: Graphical View

Learn how to load NCBI sequences into Genome Workbench (http://www.ncbi.nlm.nih.gov/tools/gbench/) and work with the graphical view.

In this video, I’ll demonstrate some of the features of the graphical view within Genome Workbench, including how to load sequences from NCBI, manipulate data tracks, control zoom level, and use hot keys. I’m starting with Genome Workbench already open. You can get Genome Workbench at the URL at the bottom of the screen. I’ll start by retrieving a sequence from NCBI and loading it into Genome Workbench. I’ll select File-Open, Data from GenBank, and type in the accession number: N T _ 0 1 1 5 1 2 . 1 1 Genome workbench allows us to set a range to start with and I’ll set that by typing: 1 8 6 5 0 k – 1 8 7 5 0 k after the accession. Then I’ll click Next, and Finish to accept this as a new project. To get the graphical view, I’ll right-click on the accession number, choose Open View, then Graphical View. You see a default set of tracks...Tiling Path, Genes, etc. You can rearrange these tracks by clicking and dragging. Here, I will move the Tiling Path above the Genes track. I can close or minimize a track using the controls in the upper right corner of the track. Here I’ll turn off the tiling path display. The content menu displays many different tracks that are available. I’ll turn the Tiling Path track back on. Although we set a range for the initial view, you can click and drag horizontally to pan. To quickly control the zoom level, hold the Z key and click and drag vertically. If you want to get back to the previous view, right click anywhere and select Back. If we select the SOD1 gene and then right click, we can Zoom to Object and zoom in on SOD1. We can again right click on SOD1 and select Zoom to Sequence to see the actual sequence. We’ve seen the Z hotkey. Now I’ll press and hold the L key, which displays additional hotkeys and zoom controls. Before I show the next feature I’m going to right click and choose Back twice. Another way to zoom is to hold down the R key and click and drag in the ruler. Finally, note the controls in the bottom of the graphical view. Here you can do things like change the look of the gene feature by adding arrow heads, change the position of labels, and change the way things are colored. That’s a quick tour of the graphical view in Genome Workbench. There are some other videos that explore more advanced features and I encourage you to watch them. Thanks.

This video is also available on YouTube. [image]http://youtu.be/-a7E_te1Oo8