# PubMed: Need the Full Text Article?

A tutorial on how to get full text articles for PubMed citations, both free and for a fee.

This video shows you how to get full text journal articles for PubMed citations. Starting from the PubMed homepage, I’ll search with the query, sports blood doping detection. PubMed result pages include a ‘Free Full Text’ link in the filters sidebar. Click the link to display articles that are freely available from the publisher. To go to a full text article, either use the links in this summary display, or click the citation title, then the icon in the abstract display. Even if a citation is not marked as free, you may want to open the citation’s abstract display and click the publisher’s icon, since your institution may have a subscription to the journal. If an article is not free, publishers or related organizations may provide access to articles for a fee or it might even be free after registering as a guest. In addition to the publisher’s icon, look under LinkOut on the abstract display. Linkout may include additional links to the full text. If you are affiliated with a hospital, university, or other institution, contact your local medical library to discuss full text options. If you need articles on a routine basis, consider using the PubMed “Send to” -- Order function. The default article order service is the NLM-sponsored Loansome Doc service. To use Loansome Doc you must first register with a delivery service. Fees and delivery methods will vary depending on the provider. Finally, some local libraries may have copies of medical journals or can get a copy of an article for you. Ask your local librarian about interlibrary loan options and charges. If you have questions about getting full text articles from PubMed, please use the link, "Support Center", found at the bottom of the PubMed pages.

This video is also available on YouTube. [image]http://www.youtube.com/watch?v=b0Rk_zmMaWw