# dbGaP: Study Registration Update - New Submission Portal Status

This is an update to the February 2014 video, "dbGaP: Complete a Study Registration" (https://youtu.be/gIjN0Er39us). This video describes the different statuses in the new Submission Portal Status part of the Manage Study page.

This video is an update to one released in early 2014 called, dbGaP: Complete a Study Registration. You can click on the note below to open that original video in a new window. We recently added a new section called, Submission Portal Status, to the study page in the dbGaP Registration system. So this video describes the meanings of each status. As with the original video, this tutorial is most useful for Principal Investigators, or PI's. I'm logged in to a test Study, and I'm on the Registered Studies page of the Submission System. The Submission Portal Status becomes available when the Registration Status gets set to Completed by GPA. The three current statuses are Pending Invite, Expecting Submission, and a table that I will describe in more detail. Pending Invite signifies that an automated invitation email was sent to the submitter, but has not yet been accepted by the submitter. Expecting Submission means that the invitation is accepted by the submitter, but no file has been submitted. Finally, there is a tabular status. The table will have two columns: File Type and Status. For the different file types, namely phenotype, genotype, anaylsis and SRA, the possible statuses are, No Sub yet, which means that a file submission is expected, but hasn’t yet started. In Process means that files were submitted and that file processing by dbGaP has started. Awaiting Re-Sub means that a submitted file or files failed the dbGaP quality control process and dbGaP is expecting resubmission. Complete means that file submission and processing is complete. And Not Expected and Expected refer to file submission. A fourth status is possible if dbGaP needs the GPA to make a correction, such as changing the consent group. In this case, Registration Status is changed from Completed by GPA to Awaiting GPA’s Approval, which unlocks the study so that the GPA can make the change, and the File Type status is set to Awaiting correction by GPA, as you see here. That is the new Submission Portal Status. Again, if you want to view the original video, click on the note below.

This video is also available on YouTube. [image]https://youtu.be/IY-7izTCB_M