# How to Submit a dbGaP Data Browser Request

This video provides step-by-step instructions for principal investigators to submit a request to view a subset of controlled access data in dbGaP. After a streamlined approval process, you can use the dbGaP Data Browser for view-only access to a compilation of individual-level data from general research use (GRU) studies.

The dbGaP Data Browser offers a streamlined request process to view a subset of controlled access dbGaP data. This video shows you how to submit such a request, and the browser is further described in the November 29, 2016 issue of Nucleic Acids Research. I'm going to start on the dbGaP homepage, and follow the link to dbGaP Data Browser under Resources. If you are not already logged in, you will need either an eRA Commons account or an NIH Login. This is true for access to all dbGaP controlled access data, not only this Data Browser. In addition, only principal investigators are allowed to access the dbGaP Data Browser, at this point in time. A principal investigator is defined as a permanent employee of their institution at a level equivalent to a tenure-track professor or senior scientist, with responsibilities that most likely include laboratory administration and oversight. After log in, be sure you are on the Data Browser tab, where you will see this button, Create New View-Only Data Browser project. I'll click that button, and you now see in the link, ÔView-only access to human genome data through the dbGaP Data Browser.' Clicking on that opens the Project Request form. This form has a prefilled Title and Research Use Statement; these cannot be altered. You then choose your signing official from the list, fill in your Institution information, and click ÔSave and Continue.Õ The next step is to fill in information for your local IT director, then click Save and Continue. At this point you must read and agree to abide by the Code of Conduct and Data Browser Use Agreement; you can open that PDF document here. Click Continue, and you are now at the last step in the request process. Here you can review the application, and you must check two boxes to agree that all of your statements on the application are complete and accurate to the best of your knowledge, and agree that you have read, and agree to adhere to the terms described in the Browser Use Agreement and Code of Conduct. Finally, click Submit Application to Signing Official. At this point, your designated signing official will receive an email notifying them of your request, and if your application is approved by the signing official, your request is routed to the NIH Central Data Access Committee (CDAC) for their review. You will receive an email notification for each stage of the process. After that approval, access the dbGaP Data Browser by logging into the dbGaP Authorized Access website, and on the Data Browser tab, you will see this link, "launch browser." In most cases, you will have access two working days after CDAC approval. Click Agree once in the browser, and you are all set. Be aware that access is granted for one year, after which you may renew access or simply let access permissions lapse, without penalty. Also be aware that your name, institution, and the date of access approval will be publically posted on the dbGaP website. This is consistent with NIHÕs policy to maintain transparency around the research use of its controlled-access data resources. That concludes this tutorial. For help using the browser once you have access, see this Help link, and videos on the NCBINLM YouTube site. Use the link on the closing screen of this video to open that YouTube playlist. If you have questions about permission requests, please write to gds@mail.nih.gov. And see the November 29, 2016 issue of Nucleic Acids Research for more about the dbGaP Data Browser.

This video is also available on YouTube. [image]https://youtu.be/8sNGaFKjmHQ