# dbGaP: Renew Authorized Access

This video reviews the steps needed to complete a renewal of authorized access for a dbGaP project.

This short video walks through the steps needed to complete a renewal of authorized access for a dbGaP project. If needed, you can get to the login page from the link, Apply for Controlled Access Data, on the dbGaP homepage. I'll begin already logged in. Under the Actions column on the My Projects page, locate the project needing renewal and click the link, renew project. Most of these tabs should be familiar. The new pages for this renewal process are Research Progress, Presentations, and Publications and Manuscripts, so if you have no changes to make on the Research Project, Collaborators, or IT Director pages, you can proceed to Research Progress. You need to supply text for Research Progress and Plans, at a minimum, and possibly amend your Research Use Statement, depending on your answers to these questions. I'm ready to move to Presentations, so I'll click Save and Continue. This section is used to list any posters or talks by you or your internal collaborators that are based on the dbGaP data in this project. You should also include future presentations that have been accepted. I've entered one presentation and will click Save and Continue. Similar to presentations, here you should list manuscripts you have published that describe your use of the dbGaP data. If you input a PubMed ID, the Look up function populates these fields for you. I'm finished here, so I'll save and continue... It is good to review the Data Security page. This is where you would indicate that you have changed institutions, or added collaborators, or had a data security issue. If you made additions to this page, click Save and Continue. One use of this renewal form is to add new datasets to the project. Be aware however, that requesting additional datasets requires amending the Research Use Statement (RUS), which can be done on the Research Project page. I'm not adding any datasets, so I'll move to the Review DUC page. If you haven't read your Data Use Certificates in a while, we encourage that you do that now, and if you've added datasets that require IRB, Institutional Review Board, approval, you will see this section called, Program-specific required attachments, that either shows the uploaded attachments, or, as in this case, provides buttons to upload the approval form in .pdf format. I have added my file and will click Continue. You need to review your Research Use Statements and check the box for each dataset, indicating that you agree to the Data Use Limitations, and then click the I agree button. We're now on the last step. Here you should review your application and either approve or revise it. I’ll check these boxes to approve and submit my application to the Signing Official. The same Data Access Committee that reviewed your initial Data Access Request will review your renewal. You will also receive emails at each step of the approval process, and you can come back at any time to check the status on the My Requests page.

This video is also available on YouTube. [image]http://youtu.be/PG9D5mUouXg