# 1000 Genomes Browser: An Introduction

Learn how to view variation and genotype data, as well as supporting sequence reads from the 1000 genomes project.

This video demonstrates the basic functions of the NCBI 1000 Genomes Browser, which allows you to explore variant calls, genotype calls and supporting sequence read alignments produced by the 1000 Genomes project. Subsequent videos will explore the browser's functions in more detail. You can access the browser from a variety of NCBI web pages, including the Variation home page and individual dbSNP or ClinVar database records. I'll start in the browser, and notice that we are currently displaying the Phase 3 dataset; follow this link to the README files for more information. I'm going to focus on 5 browser components, Search, Sequence Viewer, Exon Navigator, Subjects and Genotype Table Let's start with the Search function. First, I’m going to close the Ideogram View just to get a bit more space, and notice that as I mouse over the Search box I see a Search examples link appear. Clicking on that shows that you can search by, gene symbol, phenotype,variant ids from dbSNP and dbVar, cytogenetic band, and a variety of formats for sequence coordinates. Our example today is a dbSNP id, rs1800407. To retrieve this SNP you can click the arrow or hit the Enter/Return key. Now as I mouse over the result I can click this blue arrow and the other components update. You now see that this SNP is located in the OCA2 gene. It turns out that one allele of this variant is associated with green or hazel eye color in people of European descent. The Sequence Viewer is now centered on this SNP and displays a location marker within an exon of the OCA2 gene. Several tracks are displayed by default and you can change the displayed tracks using the Configure menu. Within the viewer you can re-order tracks, zoom in various ways, and pan. Hovering over features in a track opens a menu with additional information and links to other NCBI resources. For more detailed help, use this Help link. Hovering over the marker for our SNP brings up a menu of useful options. For example, "Marker Details" opens a window that shows the position of the marker in genomic, transcript and protein coordinates, including HGVS notation, and you can download this table for import into a spreadsheet. You can add markers by right-clicking anywhere in the display and selecting Set New Marker. Let's see what the Exon Navigator can do for us. The current exon is this open clrcle with a blue outline. Mousing over this circle highlights the boundaries of the exon in the Sequence Viewer and displays the exon coordinates. When you click a circle, the viewer moves to that exon, allowing you to quickly display different exons. To zoom out to the boundaries of the current gene, use this Region menu and select one of the Go to gene options. Depending on your zoom level, you can switch between genes in the displayed region using the Gene menu, or switch between transcripts with that menu. As you adjust the displayed sequence, the Genotype Table updates, and vice versa. Each column in the table represents a chromosomal coordinate where a variant has been called by the 1000 Genomes project. White columns correspond to the variants currently displayed in the sequence viewer, while yellow columns reflect selected coordinates, our snp in this case. Hovering over the header row of any column brings up a tool tip with variant details from the 1000 Genomes project. The second row of the table shows the global allele frequencies, while the other rows show population-specific allele frequencies. We can see that the rs1800407 variant exhibits population stratification, with the T allele being less prevalent in some Asian populations, as shown in the CDX subpopulation, and more prevalent in ancestral European populations, as shown in the CEU subpopulation. So how can I show sequence read alignments in the viewer? First, expand a population set and you see the genotypes for individual samples in that population. Next click on a box in a sample row. I’m checking the box for sample NA 7000, then the box for the exome data, which you see is stored in this SRA read set. The display updates and we now see the heterozygous genotype at this position. Matches to the genomic reference are shown in gray, and differences in red. You can also choose alignment tracks in the Subjects section. I'm going to expand this window a bit by grabbing and pulling the corner. Available alignment tracks are in the bottom section of the window; as you scroll down more tracks are loaded. And the Filters section is where you can narrow the displayed tracks. When you check a filter box you see the number of available tracks change. Or, you can do a free text search of the tracks. I'll paste in search for a specific sample, NA12878, then select tracks of interest from the results and click Update Tracks to add them to the display. In contrast to NA07000, we see that NA12878 is homozygous for the reference allele at this SNP. You can remove tracks by deselecting them in the Subject widget and clicking Update Tracks, or in the Configure menu, or with the red X. And as expected, any track selections made in the Subjects subwindow will appear in the Genotypes table, and vice versa. Finally, the Download section provides options to download the SRA reads or the genotype data for the displayed region. That's a brief introduction to the 1000 Genomes browser. For additional help, follow the FAQ and Help links near the top of the page. And you can write to the Support Center via the link near the bottom of the page.

This video is also available on YouTube. [image]https://youtu.be/zCMws0YVeG4