# BLAST: New Results Format

An introduction to a new web BLAST (http://blast.ncbi.nlm.nih.gov/) results format released in October 2012.

This video introduces the new web BLAST results page available in October 2012. Subsequent videos will go into more depth about how to use certain features and programs. Some of the features that I will discuss here are: Customizable table in the Descriptions section Navigation within the page Download the aligned region of a hit in FASTA format Display a new Graphics view of the aligned region Faster loading of alignments Links to other resources Let's take a look at the new Descriptions section. First, note that more of the description, or definition line, is available. In addition, this table can be customized to remove columns you may not need; use the gear icon to make your selections. For example, after removing the accessions, I can now see which transcript variants were found. The number of descriptions displayed is still limited by the setting in 'Max target sequences' on the submit page, which is 100 by default. To view a specific alignment within this page, you would click on the description, or you can click on Alignments. IÕll stay here in the Descriptions section, and notice that many options are unavailable, see the grayed out text, until at least one description is selected. One of the most important new features is that you can now download only the aligned region of the subject or hit sequence. And, although not new, these columns can be sorted by clicking the column name. The Graphics link takes you to a Sequence Viewer display of the alignment that may include known features on the query, such as the exon structure, protein product, and SNPs. The alignments are represented here. You will only see such features when using an NCBI accession or gi identifier as your query, particularly RefSeq identifiers. Use this help icon to access Sequence Viewer help, including video tutorials. Be aware that the Graphics links from the Alignments section, which IÕll move to next, show features of the hit sequence, not the query. I'm now in the Alignments section. Here, the Download menu acts only on this one alignment. In cases where more than one alignment is made to the subject sequence, you can sort the alignments, and the different Graphics or GenBank links optimize the intial view for either the whole subject sequence or for the specific alignment. A key change is that the results page will often load into your browser more quickly, because not all alignments are initially loaded. As you scroll down the page, more alignments are loaded, or clicking on a hit the Description section will load that alignment if it is not initially displayed. Finally, the icons representing linkouts to other NCBI resources are now links in the Related Information section. We encourage your input, so please use this link to provide feedback.

This video is also available on YouTube. [image]http://youtu.be/yfITRIk34Js