# BLAST Results: Expect values, part 2

Answers to a few common questions about BLAST (http://blast.ncbi.nlm.nih.gov/) that we get at NCBI.

In part 1 of the companion video, I gave a very simple explanation of Expect, or E-values, and how they are used. Here, I’ll answer a few common questions about E-values that we get at NCBI. Question #1: How are scores and E-values related? In simple terms, the higher the score the lower the E-value. This makes sense in light of the simple definition of E-value, the number of hits you expect to see by chance. It also makes sense if you think of E-values as a false positive rate. Take a look at formula #3 in “The Statistics of Sequence Similarity Scores”, which has a link on the BLAST Help page. In addtion to defining a normalized, or bit, score, formula #3 also states that E-values are proportional to the product of the query and database lengths. The current blast programs subsume this product in a calculation called the effective search space. The practical implication is that E-values cannot be directly compared when searching different databases. Even identical alignments from searches of different databases will receive different E-values; the bit scores, however, will remain the same. Quesstion #2: What is the highest, or poorest, E-value that I should consider as significant? This is one of the most frequently asked questions about E-values, and the least answerable. There is no magic cutoff, you will have to decide what is significant based upon your goals and sequences. Let’s look at a couple examples that may help clarify this point. In a typical blastp search with a query of 100 amino acids against a large database like refseq_protein, the full-length, 100% identical alignments might have E-values of 2x10-61 or lower. Note that in BLAST we tend to use the notation, 2e-61. But, what if you search a large database with an 8 amino acid query? The best alignment you can get is 100% identical over 8 residues, and that is likely to have an E-value around 1 or higher. If what you know, or hypothesize, about that motif is consistent with the biological function of the database sequence, then the alignment may indicate biological relevance, even though such relevance can not be inferred on statistical grounds alone. I mentioned in part 1 of the companion video that at NCBI we use a cutoff of 1x10-6 for some internal processes using blastp against the BLAST nr database, but that may be too restrictive for your purposes. Quesstion #3: What is an E-value of 0.0? E-values are written as 0.0 if the calculated value is less than 1x10-179. If you have other questions about BLAST, write to: blast-help@ncbi.nlm.nih.gov

This video is also available on YouTube. [image]http://youtu.be/Z7ek7UoP7Bg