# BLAST Results: Expect values, part 1

A simple description of the meaning and use of BLAST (http://blast.ncbi.nlm.nih.gov/) Expect values.

This is a simplified guide to the meaning and use of Expect values as provided by BLAST, the Basic Local Alignment Search Tool at NCBI. I’ll start with about the simplest possible description of what an Expect, or E-value, is: The number of BLAST hits you expect to see by chance. To be more correct I’ll add, with the observed score or higher. And a hit, here, is simply an alignment. Let’s say you have BLAST alignments with E-values around 1. Our definition tells is that some of these alignments could easily be due to chance. This BLAST search also produced an alignment with an E-value of 2e-61. You expect to see that alignment 2x10-61 times by chance; in other words, it’s not random. A common interpretation is that if the alignment is not due to chance, then it may be due to a biologically meaningful relationship between the two sequences. Does a low E-value like this prove that the two sequences are homologous? No. BLAST does not measure homology, but you might infer homology from good alignments like this. Another common question is, how low an E-value do I need to say that two sequences are related biologically? There is no single answer, because E-values depend on query and database lengths. At NCBI we use a cutoff of 1x10-6 for some internal processes using blastp against the BLAST nr database, but that may be too restrictive for your purposes. So, the primary use for E-values is to help answer the question, “Is this alignment meaningful?” Another use is to limit your BLAST output by setting an E-value threshold. If you only want to see results with E-values better than, say, 1x10-6, then enter 1e-6 in the threshold text box. Finally, since my example is in blastp, I have to mention compositional adjustments. These statistical calculations are applied by default to provide more accurate E-values based on the amino-acid composition of the two sequences being compared. Use the help icon to get further information and references. In the separate video - Expect values, part 2 - I’ll answer some common questions about E-values that we get at NCBI.

This video is also available on YouTube. [image]http://youtu.be/nO0wJgZRZJs