# BLAST: Create Custom Databases

A step-by-step tutorial showing how to limit your web BLAST searches to a customized set of sequences.

Create Custom Databases for Web BLAST An often overlooked feature of web BLAST is the ability to search a database tailored to your needs. Maybe you want to search just one organism, or a larger taxonomic group, or exclude certain organisms. Maybe you want to search only proteins with solved structures, or nucleotide sequences of a given length range, or only sequences with PubMed references. All this can be accomplished in a few quick steps and the more concise BLAST output not only makes it easier to find the hits you want, but may allow you to analyze more queries in a single search because of the smaller database. Let's look at two example databases. Say you want to search annotated genomes from primates. Starting on the BLAST home page, go to the nucleotide blast page, select the refseq_genomic database, and start typing primates, select taxid 9443, and that's it. Next is a more involved example showing the power of Entrez queries. Say you want to search proteins from all Xenopus species that have a calculated molecular weight between 10 and 100 kDa, and which have a direct link to the Structure database. I"ll start on the protein blast page, keep the default database, nr, type xenopus in the Organism field, select taxid 8353, and add this Entrez query: 10,000 colon 100,000 followed by the field, molecular weight, in square brackets. Then in all caps, AND, followed by protein structure and the [filter] field. That completes our second example database, but I want to give you a few more tips on using Entrez queries. You can use this range syntax, that is, the colon, with other fields, including sequence length. Note that sequence length works for nucleotide databases as well as protein. And since I mentioned it earlier, you can restrict your search to sequences with direct links to PubMed by using the term, protein pubmed[filter], or nuccore pubmed[filter] if searching a nucleotide database. We strongly recommend that you test your Entrez queries in the appropriate NCBI database before using them in BLAST. For our Xenopus example that would be the Protein database. I'll search with this query ... xenopus[orgn] AND 10000:100000[molwt] AND protein structure[filter]...and we get a nice set of results with no error messages. You can follow this Help link to discover other possible Entrez queries. I am going to switch back to the nucleotide blast page for a moment to emphasize that a key step in creating your custom database is the initial choice of parent database. For example, if you want to search WGS, the whole genome shotgun, contigs, be sure to change from the default, nt, which excludes those records. For wgs searches, Entrez queries are not allowed, but other options are available. For help with the contents of these databases, use the question mark link next to the database selection menu and this guide to the BLAST pages, which is found on the BLAST Help page. If you have trouble or need advice, please write to blast-help@ncbi.nlm.nih.gov.

This video is also available on YouTube. [image]http://youtu.be/t8fKz9rvuOk