# Genome Workbench: Search and View a Gene

Learn how to retrieve and view sequence records from NCBI using Genome Workbench (http://www.ncbi.nlm.nih.gov/tools/gbench/).

In this video I'll show how to use Genome Workbench to search the public NCBI databases for a specific gene and then display it graphically. From the search tool menu, we'll choose Search NCBI public databases. And we want to make sure that we're searching the Entrez Gene database. In the search box we'll type our gene symbol, in this case SOD1 and we can either press return or click the green triangle. The search is returned, we'll select SOD1 that corresponds to the organism Homo sapiens and then we can right click on it, and choose 'Add to Project.' We'll choose to create a New Project and we'll say OK. In our project tree view we have a New Project with a data folder and the gene that we found in the NCBI database. Here we can click on it and then right-click and choose 'Open View.' We'll choose a 'Graphical View', the item whose prefix begins with NG and click finish. Now we have a graphical view showing the gene. The green bar represents the gene, the blue image represents the mRNA and the red image represents the protein. As we hover over these different graphical images, we see tool tips that appear and they show us lots more information. While looking at this we can click and drag to pan left and right and then if we hold down the 'Z' key we can zoom in. We can zoom all the way down to the sequence. We can zoom back out. We can hold down the 'R' key for region zoom, click and drag, and we can zoom in again. If we double click the gene, we'll zoom out so that we see it filling the view. Very quickly that's how you find things in the NCBI public databases and look at them graphically.

This video is also available on YouTube. [image]http://youtu.be/ZIUfS4S43kM