# Save Searches and Set E-mail Alerts

Save searches and set up e-mail alerts for new results in many NCBI databases. This video is a cosmetic update to the video released on May 8, 2013.

This video quickly demonstrates how to save searches and set up automatic e-mail alerts for new results. Searches are saved in your free My NCBI account. I'll demonstrate with a search of PubMed, but these save and email functions are available for many NCBI databases. I'll search PubMed with the term, neanderthal. You see that a Create alert link appears near the top of the page, whether or not you are signed in or even registered for My NCBI. I'll click Create alert. If you are not signed in, you are taken to this page, which also has a link to register a new account. I'll go ahead and sign in. Here, you can change the name of your search, if you like. If you would like to receive e-mails containing new results for this search, schedule the updates here. Note that the report formats change depending on which database you searched. Once you are satisfied with the settings, click save. You can change or cancel e-mail updates at any time in the Saved Searches area of your My NCBI account. That's a quick look at setting up e-mail alerts. Visit the NCBI on YouTube, at the address shown, for more tutorials. www.youtube.com/user/NCBINLM

This video is also available on YouTube. [image]https://youtu.be/WbFjV91YNNY