# Sequence Viewer: Using BLAST

How to use BLAST within NCBI's Sequence Viewer (Graphics display).

In this video I’ll demonstrate how to use the Graphical Sequence Viewer to start a BLAST search and to show the results. I’m going to start with Sequence Viewer already open, showing a portion of Human Chromosome 1. The URL for this is at the bottom of the screen. For more information about BLAST, see the BLAST home page at NCBI. From here, I’m going to click on in the ruler and drag around the section that will be my query sequence. That is, I’m going ask BLAST what this sequence aligns to. So now that I’ve highlighted a region, I’m going to right click, or control click, to bring up the tools menu. From here, choose BLAST. Now we see the BLAST page with many parameters we can tune, but we’ll accept all the defaults and click BLAST. BLAST can take a few seconds to run. When BLAST returns we see the BLAST results presented in the Graphical Sequence Viewer. We can zoom in to see the details of our alignment. For this case let’s use the Go To Range Tool and see a particular region. Type in: 1 5 4 2 9 5 0 0 0 : 1 5 4 2 9 5 1 0 0 And click Ok. Sequence Viewer will zoom to that range, where we can see all four possible outcomes. First, pan to the right a little bit. All the bases in grey represent matches, those in red represent mismatches, and blue triangle represents an insert and the blue horizontal line represents the number of bases that are inserted. In this case just one. And the red horizontal line represents a deletion and it is proportional to the number of bases deleted, Again just one in this case. So this is just a start using Sequence Viewer and BLAST. There’s a lot more you can do with both tools. Please check them out. Thanks!

This video is also available on YouTube. [image]http://youtu.be/cSlW05LDMlM