# Sequence Viewer: PDF Rendering Feature

How to generate a PDF rendering of your Sequence Viewer display. View the rendering in your browser, share the link, or download a .pdf file.

This tutorial demonstrates how to use the NCBI's Sequence Viewer PDF rendering feature. I'll start in the Graphics view of this human chromosome 22 record in the Nucleotide database, but many other NCBI databases, such as Gene, also incorporate a Sequence Viewer display. Let's say we want to capture a much smaller region for our PDF. I'll select this region, click Zoom on Range, then in the Tools menu, I'll go to Download and select PDF file. Sequence Viewer now displays the Download PDF file dialog. You can change the coordinates here to some extent. I'll increase the range slightly. This will show a larger region in the PDF rendering, but the zoom level will not change. That is, the PDF will contain the same level of detail, such as the exons seen in these gene features. Notice that Simplified color shading is checked by default. If you plan to print your PDF file right away you should probably uncheck it for better coloration. But, if you plan to edit the picture in a graphics editor, say, for a poster or journal article submission, you should leave the box checked. I'll leave it as is and click the Create PDF-file button. A link to the PDF file is generated, which you can share with colleagues. These links are stored on NCBI servers for about two weeks. In most browsers, clicking the View button shows the graphic in a new tab, as shown here. Or you can save the PDF to your computer. For editing, we have tested the generated PDF files with Adobe Illustrator, Adobe Acrobat Pro, and InkScape, but other editors may work just as well. Of course, you can just cancel PDF generation and continue using the Sequence Viewer. Visit the NCBINLM YouTube channel for other video tutorials.

This video is also available on YouTube. [image]http://youtu.be/oym8dPB0BSE