# Using Primer BLAST

A quick demonstration of how to initiate Primer-BLAST from within the graphics, or sequence viewer, display in nucleotide records at NCBI.

In this video I’ll show how to use Primer BLAST to graphically find a set of primers using Sequence Viewer. I’m going to start with Sequence Viewer already open showing the Human beta globin region. The URL for this is at the bottom of the screen. I’ll zoom in on HBE1 by clicking in the ruler and dragging around the feature. I'll right click or control click and choose Zoom on Range. Now I’ll select the region by clicking and dragging in the ruler and then right clicking or control clicking to bring up the contextual menu. From this menu, choose Primer BLAST. Notice that some of the fields are already filled in. For this example, I’m going to uncheck the Specificity Check. However when you’re doing this for real, you should rely on your own expertise to decide whether to check this or not. Primer BLAST produces results much faster, and with a different meaning, with this unchecked. Ensure the ‘Use new graphic view’ is checked and click Get Primers. When Primer BLAST returns, we see the results presented graphically. If we go back to Sequence Viewer Showing the feature, we can select the region in a slightly different way. I’ll select two regions, one on either side of the feature for the forward and reverse primers. Select by clicking in the ruler and dragging, then hold control, or command, and click and drag for the second region. Then right click in the ruler and choose Primer BLAST. The parameters for the forward and reverse primers are automatically filled in. Uncheck the Specificity Check. Ensure that Use New Graphics View is checked and click Get Primers. And again, I see the results graphically. There’s a lot more you can do with Primer BLAST, but that’s for another video. Thanks.

This video is also available on YouTube. [image]http://youtu.be/wKw2yLHLYgU