# Phylogenetic Trees: Using Genome Workbench

Create a protein multiple sequence alignment and generate the phylogenetic tree using Genome Workbench (http://www.ncbi.nlm.nih.gov/tools/gbench/).

In this video using Genome Workbench I'll demonstrate how to create an alignment of proteins using an external tool, followed by generating a PhyloGenetic Tree. To get started we're going to search the NCBI public databases. We're going to look in the Protein database; and we're going to search for the organism Collembola[orgn] and the author Hebert[auth]. We can either press to return, or click the green triangle. Our search returns sixty items, we're going to select all of them. We're going to right-click and say 'Add to Project.' We're going to create a new project and say OK. In our project tree view we have a new project with a data folder with our sixty items in it. We're going to select all sixty of those items; we're going to say right click and run tool. In the 'Run Tool' dialog we're going to choose the MUSCLE alignment tool. The MUSCLE alignment tool is not provided with Genome Workbench but can be downloaded from the link at the bottom of the screen. We have to tell Genome Workbench where to find MUSCLE. We say 'Open'. And we tell Genome Workbench to 'Go' And we're going to add it to our new project. We'll say finish. We can see that MUSCLE is running. And there's our MUSCLE alignment. Again we'll right click, we'll run a tool, we're going to find the Phylogenetic Tree builder tool. And we'll say 'next.' We'll add it to this project. And there's our tree. And now we'll say open view and we'll choose a tree view. And we have our Phylogenetic Tree. Here we can do everything we've been doing with zooming. We'll click on the 'Z' key and we can zoom in and as we get closer we can see labels. We can click on nodes and get tool tips. And very quickly that's how we can create a Phylogenetic Tree using gBench.

This video is also available on YouTube. [image]http://youtu.be/hKqZtsdhxks