# Obtain Genomic Sequence For and Surrounding a Gene

How to get sequence for a gene region, including how to get surrounding sequence.

This tutorial describes part of the How To called, "Obtain genomic sequence for or near a gene, marker, transcript or protein." I'll focus on obtaining sequence for and surrounding a gene. Let's get sequence for the human EME1 gene. I'll start on the NCBI home page, type eme1 AND human, followed by the organism field tag, abbreviated o-r-g-n, in square brackets. Then I'll select the Gene database, and click Search. Open the record by clicking the gene name. You might first take a quick glance at the "Genomic context" section. Here the highlighted arrow, and the arrowheads, point to the right, so this is a plus strand gene relative to the chromosome 17 annotation. A good way to get the genomic sequence is right here in the "Genomic regions, transcripts and products" section.Hover your cursor over the gene feature, then click the little "i" icon in the upper right of the box.If you prefer, you can also right-click on the gene feature and select Properties, then go to either the FASTA or the GenBank views. I'll go to the GenBank view. If you want the entire genomic sequence for the gene, including any UTR's, the untranslated regions,go to Send -> File -> choose the format, then click the Create File button. If you want to include, say, two kilobases of upstream sequence, decrease the "from" coordinate by 2000, click Update View, then download as before. Note how the number of base pairs increases by 2000. If you want only the upstream two kilobases, also change the "to" coordinate to the original "from" coordinate value, minus 1 you I want exactly 2000 bases. The procedure for getting surrounding sequence is the same when your gene is on the minus strand, as long as the box is checked for "Show reverse complement." Another way to get genomic sequence, for example just a UTR, or exon or intron, is from the Gene Table display. Go back to the top of the Gene record and change "Display Settings" to Gene Table. The ranges shown in the table, down in the page, are links to the sequence. Note, also, the link to the very helpful "Gene Table help."

This video is also available on YouTube. [image]http://youtu.be/RHz2nZbzjpA