# Navigating the NIH Manuscript Submission Process

Get detailed help in submitting, reviewing, and approving your manuscript in the NIHMS (NIH Manuscript Submission) system.

The NIH Manuscript Submission system, the NIHMS, allows authors and principle investigators to submit manuscripts for archival in PubMed Central. This video has two parts, submission, and post-submission review. The second part starts at about 6 minutes, 40 seconds into the video. Let's begin the submission process on the log in page. In the upper right corner you find information about NIHMS as well as help documentation, including an FAQ, Tutorials, and a Glossary. Begin your submission by signing in through one of several sign-in routes designed to accommodate users from many institutions. Guidance on signing in is available in the FAQ and Tutorials. I've now logged in and I see a manuscript list organized into five tabs: The ÒNeeds Your AttentionÓ tab displays manuscript submissions that are awaiting your action; ÒIn Process in NIHMSÓ displays submissions undergoing action by NIHMS staff or other parties; The ÒStalledÓ tab displays submissions that have been awaiting the ReviewerÕs action for over 4 weeks. By the way, information for authors or PIs interested in taking over Reviewer duties for these submissions is available in the FAQ; The ÒCompletedÓ tab displays submissions approved by the Reviewer that are awaiting either final citation information or expiration of a publisher-mandated embargo prior to release to PubMed Central; and finally, The ÒAvailable in PMCÓ tab displays submissions that are complete and in PMC. I want to point out that from anywhere in this system, you can view and edit your account information by clicking on your username in the upper right-hand corner of the screen. And notice the Stage-specific instructions on the right-hand side. These accordian menus are present on all pages to help guide you through the process. To begin a new submission, click the "Submit New Manuscript" button. You are first asked to provide the manuscript and journal titles via one of three methods. Option 1 is manual entry. The Journal Title field will suggest possible titles based on your input. Option 2, which I will use for this demonstration, allows you to search for the manuscriptÕs PubMed record and import the title information from there. You can search using the same search terms that you would use on PubMedÕs website, such as author name or article title. Then select the publication you wish to use from the search results. Option 3 allows you to pull the title information from your My Bibliography in My NCBI, if you have already added the citation to My Bibliography. Please note that this method cannot be used for citations created manually in My Bibliography. Once you've provided the title information, you can proceed to the Add Funding step to associate funding support. This step is required only if you are an author or PI serving as the Reviewer for the submission. Otherwise, the Reviewer can associate the funding when approving the submission for processing. You may search by the PI's name and/or the grant/project ID number. Because many grants change PIs over the years and have multiple subprojects with different PIs, we recommend using a combination of the PI's last name and the grant number to retrieve the best results. Also, be careful with the grant number format, as that will affect the results of your search. If multiple results are returned, they are listed only as suggestions, and you must select the applicable funding by clicking the corresponding check boxes before proceeding. PIs with more than three grants will not have their full grant list displayed by default. Click the ÒShow MoreÓ link in the Search Results section to view all available options. I've selected one grant and will now go to the Upload Files stage. All files associated with the peer-reviewed, accepted manuscript are required, including all parts referenced or called out in the text. This includes the title page with the author and affiliation, the main text of the manuscript, references, figures, tables, appendices, and supplemental materials. To upload a file, click on the "Choose file" button next to the appropriate file Type and select the file from your computer. You can add more fields for file types using the links below the file list, and be sure to include a unique and descriptive label for each figure, table, or supplemental file, as well as any additional manuscript files. Once all required files have been added, click the "Check Files" button. You may see a brief window showing the progress of the download, then on the Check Files page, you will see a status bar indicating that the PDF Receipt is being generated. Once complete, the status bar will be replaced with a link to the PDF Receipt. You are required to review this document before proceeding to the next step. Once you have reviewed the PDF Receipt, you can either go back to the Upload Files stage to change, add, or remove files or proceed to the next step by pressing the "Set Reviewer & Embargo" button. This step requires you to either (a) assign the submission to an author or PI for review, in which case he or she will receive detailed instructions via email for accessing the manuscript and completing the initial approval process, or (b) if you are the author or PI and wish to approve the submission yourself, set the embargo and click the ÒApproveÓ button. When approving the submission yourself, you will also be asked to read and accept the submission statement, a legal document that confirms that you have the necessary authorization to provide the files you submitted for Public Access; that you are an author of the manuscript; and that your NIHMS submission does not otherwise violate any agreements you have made with the publisher. If after reviewing the submission statement you need to adjust the Embargo, you can do so by clicking the ÒChange Release DateÓ button. If for any reason you disagree with the submission statement, click the ÒDisagreeÓ button to submit a comment, and an NIHMS staff person will assist you. Upon accepting the submission statement, you will see a summary of the process you just completed, and the next steps will be listed for you. Post submission, your manuscript is processed by NIHMS staff, to generate xml markup and supporting files. Once those files are complete, they will notify you so you can review them and request any corrections before your manuscript is released to PubMed Central. That ends the submission part of the process, so let's now go to the review and approval part. At this point you have approved your submission for review or processing, and it has made it through the conversion process. You should have received an e-mail asking you to sign in to the NIHMS system and review the web version of your manuscript. Once signed in, you will see the manuscript in the Needs Your Attention area of your Manuscript List. Click on the manuscript title to access the submission record. On the next screen you will find a link to the PMC-ready documents that require review, as well as a link to the originally submitted files, if you wish to compare the two. There is also a second version of the PMC-ready documents that includes paragraph numbering to reference when reporting any necessary corrections. Once you review the documents, you can approve them for release to PMC or, if corrections are necessary, use the ÒRequest CorrectionsÓ button. On this screen you will again have access to a version of the PMC-ready documents with paragraph numbering. Enter the paragraph number in the "Location" field and the correction data in the "Correction" field. Correction requests should be clear and concise, referencing excerpts from the text whenever possible. And you may add more rows to the correction request form by clicking Add another correction. Once you have entered all the corrections, click the ÒSend CorrectionsÓ button. NIHMS staff will process the corrections and update your manuscript accordingly. Once the updates are complete, you will be asked again to sign in and review the revised PMC-ready documents. If no further corrections are required, approve the manuscript for release to PMC to complete the submission process. I'll just cancel the corrections request, then click the Approve button. Upon final approval, you will see a confirmation page indicating when the manuscript will be available in PMC. A PMCID is assigned after the submission is approved and matched to a PubMed citation, at which time the status indicator for the publication in your My NCBI bibliography will also update to reflect the new compliance status. If, following final approval, your manuscript is still Awaiting final citation information, which you can see on the Completed page, please note that the NIHMS system includes a feature that allows authors to provide citation information to NIHMS staff. At any time you can click on the "Provide Citation" link to provide this information. You may also receive an email if NIHMS staff are unable to locate the citation. In that case, follow the instructions outlined in the request to access the citation form, or simply reply to the email, and NIHMS staff will be happy to assist you. That concludes our demonstration. If you still have questions, please see the Step-by-Step Tutorials page and the section called Additional Help.

This video is also available on YouTube. [image]https://youtu.be/IIEBtfnSqMA