# Genome Workbench: Loading a Genome

This video shows how to search for and load an entire genome into Genome Workbench (http://www.ncbi.nlm.nih.gov/tools/gbench/) and choose the pieces you want to work with.

In this video I’ll show how to search for a complete genome using Genome Workbench from NCBI. I’ll start with Genome Workbench already open. You can get Genome Workbench at the URL at the bottom of the screen. www.ncbi.nlm.nih.gov/tools/gbench To get started I’ll choose Open from the file menu and click on Genome. From here I can type human, zebra fish, cow or use any of these search terms. I’ll stick with human for now and click next. This panel shows all the assemblies NCBI knows about that are human and you can pick one. gBench also displays the name for the assembly with common alternates, along with some other information about the class of assembly, release type and date. I’ll scroll down and select GRCh37, which is also hg19 and click next. Then click finish to create a new project. Now we have the data we can do all the usual things with it. Open a graphical view, by right clicking or control clicking on the data and selecting open view and then Graphical View. From this dialog we can select the particular chromosome we want to see. I’ll pick chromosome 3 and click finish. And we have a standard gBench graphical view and you can do all the usual things like zooming and panning. All the features are described in another video. A different view of the GRCh37 Data is to open a table view. To do this, right click or control click on GRCh37 and choose open view. Near the bottom, choose Generic Table View. In this view, again I can click on a row and show a graphical view, but I also get a sense of the assembly. First I’ll sort by the Chromosome column. If I look at this row, NC_000009.11, it represents chromosome 9. The four rows above it are NT scaffolds associated with chromosome 9 and unlocalized. That is, we believe they belong on chromosome, but are unable to correctly order and orient them on the chromosome. To really see the assembly in detail visit the Genome Assembly pages at NCBI. As always with gBench, this is just the tip of the iceberg of what you can do. Visit the NCBI website to learn and do more. Thanks!

This video is also available on YouTube. [image]http://youtu.be/6K6pimaFpiQ