# How to View Epigenomic Data Tracks

A tutorial demonstrating how to view track data in NCBI's Epigenomics resource.

This video is also available on YouTube. [image]http://youtu.be/dM9_ieXzAr8