# How to Download Epigenomic Data

A tutorial showing how to download epigenetic data tracks from the Epigenomics database at NCBI.

This video is also available on YouTube. [image]http://youtu.be/BT1pwf460VY