# How to use the Epigenomics Sample Browser

A tutorial showing how to search for experiments and samples in the Epigenomics database at NCBI.

This video is also available on YouTube. [image]http://youtu.be/n68QAqHlcv8