# GEO2R: Analyze GEO Data

A tutorial on how to use GEO2R (http://www.ncbi.nlm.nih.gov/geo/geo2r/) to analyze microarray data in GEO and retrieve a list of differentially expressed genes.

This video demonstrates how to use GEO2R to analyze microarray data and to retrieve to a list of differentially expressed genes. For this example, IÕm going to analyze GEO Series GSE18388. Reading the summary, we learn that this study is designed to investigate how gene expression changes in the thymus of mice that have been subjected to 13 days of spaceflight. To start analyzing this study, scroll down the page and find the ÔAnalyze with GEO2RÕ link. Click on this link and you will be taken to the GEO2R analysis tool. Before we get started with the analysis, note the ÔFull instructionsÕ link at the top of the page. This link provides details about the edit options and features that are not covered in this video and references for the R Bioconductor statistical tests that form the basis of this tool. It also provides an important section detailing GEO2R ÔLimitations and caveatsÕ that users need to be aware of. Going back to GEO2R, the table lists the samples in this study, and their descriptions as extracted from the original records. We can see that this study examines 8 samples and that the variable is that 4 of the samples are derived from the mice that were flown in space and the other 4 are from the ground control mice. The first thing we need to do is to define the groups of samples that we want to compare. Click ÔDefine groupsÕ and type a group name into the box. I can name the groups anything I want, but in this case IÕll type in Ôspace-flownÕ, click enter, and ÔcontrolÕ, click enter. Next, we need to assign samples to each group. To do that, I click a row and simply drag the cursor over the relevant samples. Then I click the group name that they belong to. Repeat these steps for each group. In this study, IÕve created only 2 groups, but GEO2R supports creation of up to 10 groups for more complicated studies. After defining your groups, scroll down to the tabbed section. You can perform the comparison straight away with default settings by clicking the ÔTop 250Õ button. However, itÕs usually good practice to first check the distribution of the expression values that we are about to compare. To do that, use the ÔValue distributionÕ tab and click ÔViewÕ. This tool calculates the distribution of the expression values for each selected sample and displays the data as a box plot. In this case, the distributions look good - the box plots are median-centered indicating that they are comparable, and so we are happy to proceed with the analysis. So we go back to the GEO2R tab and then perform the analysis by clicking the Top250 button. After a few moments, a table of the top 250 differentially expressed genes is presented Ð the table is sorted by significance, based on P-values. I can click on any row to view the gene expression profile of that gene. For example, if I click on the top hit, which is gene Rbm3, I reveal a chart where the red bars represent the expression level of Rbm3 in each sample. The group names we created earlier are listed along the bottom of the chart. So in this case we see that Rbm3 is more highly expressed in the thymus of the space-flown mice compared to the controls. I can edit the content of this table using the ÔSelect columnsÕ feature. This opens a dialog box that lists all the available statistics and annotation columns. For example, I can choose to hide the t-statistic and the B-value, but expose the ÔGene ontology FunctionÕ annotation. Click ÔSetÕ and the table content is modified accordingly. To save the full set of results and/or retrieve data beyond the top 250 genes, I can click on the ÔSave all resultsÕ link which exports the full set of results as a tab-delimited table. If I want to change any of the test options, I can go to the ÔOptionsÕ tab, make the edit, go back to GEO2R and click ÔRe-calculateÕ to perform the test with the new settings. Note that the R script that was used to perform this analysis is provided in the ÔR scriptÕ tab - you can save this as a reference for how an analysis was performed. Finally, if youÕre only interested in seeing the behavior of a specific gene within the study, rather than retrieving the top 250 differentially expressed genes, use the ÔProfile graphÕ tab. You first need to search for your gene of interest within the Platform record, and copy its identifier from the ID column. A link to the relevant platform record is provided here. For example, IÕve determined that my favorite gene, H2-M2, has ID 10450880 - when I type that ID into the box, and click set I retrieve the profile graph for that gene. That concludes this demonstration of GEO2R, if you have any questions, please email the GEO team using the link at the top of the page. Thank you.

This video is also available on YouTube. [image]http://youtu.be/EUPmGWS8ik0