# Sequence Viewer: Flip Strands

How to flip strands and reset the origin in NCBI's graphical sequence view

In this video, I’ll demonstrate some of the new features we’ve added to the graphical viewer to make resetting origins and flipping strands more clear. I’ll show this by finding the A2M gene on chromosome 12. I’ll start with the graphical view already open to chromosome 12 from the URL shown below. From here I’ll search for the gene A2M. In the search results box, here’s A2M and it’s on the negative strand. I’ll select it and close the dialog. I want to reset the origin to the start of the gene’s initiation codon. To find that spot, I’ll use the HGVS term and search for NM_000014.4, which is the gene’s accession, followed by a colon and c.1 Where c.1 means the first nucleotide in the initiation codon. The viewer then places a new marker at this position. From here, I’ll hover over the marker and then copy the position. Now to reset the origin to the beginning of the gene, I’ll right click on the ruler and choose set Sequence Origin at Position. In the dialog, I’ll paste in the position I copied earlier. Now we see the ruler’s changed. We have this new ruler on the bottom that measures in the reset coordinate frame and the top ruler is the original. We also show this red part of the ruler. The red always points toward the start of the submitted sequence. This keeps us oriented now and also when we flip strands. And we can do that to present the gene on the other strand. From the Tools menu, click on Flip Strands. We see our origin is still at the start of gene but the red points the other way now because we’re looking at the complementary strand. There’s also a ‘C’ in the title to remind us this is the complementary strand. Ok, so now let’s select a range. If the origin’s reset, selections happen in reset coordinates. So, for example, let’s show the range from 1k to 2k. Because the origin has been reset, the viewer does know which side of the origin we’re referring to so we have to tell it. We do that in this dialog. Here we see the origin with red representing the direction toward the submitted sequence origin, then we have to tell the viewer if we 1000 to 2000 on the left of the origin, 1000 on the right and 2000 on the left, 1000 on the left and 2000 on the right, or both 1000 and 2000 on the right. In this dialog, the more negative number is closer to the submitted sequence origin. I’ll choose 2000 toward the submitted sequence origin and 1000 on the other side of the reset origin. We can avoid this dialog if we use plus and minus signs in the find box. For example, if I find -1k to -2k we get exactly that range. This range is on the red side of the origin, pointing toward the submitted sequence origin. As always, there’s more you can do. Please visit the NCBI website.

This video is also available on YouTube. [image]http://youtu.be/viYz0-qy2B4